# Technical Expert Panel

Patrick M.M. Bossuyt, Ph.D.

Professor of Clinical Epidemiology

University of Amsterdam

Amsterdam, The Netherlands

Mark Brecher, M.D.

Chief Medical Officer

Laboratory Corporation of America

Burlington, NC

Michele Caggana, Sc.D.

Deputy Director, Division of Genetics

Wadsworth Center, New York State Department of Health

Albany, NY

Daniel H. Farkas, Ph.D., H.C.L.D.

Laboratory Director

Sequenom Center for Molecular Medicine

Grand Rapids, MI

Cathy Fomous, Ph.D.

Senior Health Policy Analyst

Office of Biotechnology Activities

National Institutes of Health

Bethesda, MD

Constantine A. Gatsonis, Ph.D.

Professor of Medical Science

Director, Center for Statistical Sciences

Acting Head, Biostatistics Section, Dept of Community Health

Brown University

Providence, RI

Louis B. Jacques, M.D.

Director, Division of Items & Devices

Coverage & Analysis Group, OCSQ

Centers for Medicare & Medicaid Services

Baltimore, MD

Richard A. Justman, M.D.

National Medical Director

United Healthcare

Edina, MN

Jeffrey A. Kant, M.D., Ph.D.

Director, Division of Molecular Diagnostics

Department of Pathology

University of Pittsburgh Medical Center

Pittsburgh, PA

Penny Keller, B.S., M.P., ASCP

Medical Technologist

Centers for Medicare & Medicaid Services

Baltimore, MD

Karen Kuntz, Sc.D.

Professor

University of Minnesota School of Public Health

Minneapolis, MN

Ira Lubin, Ph.D., FACMG

Geneticist

Centers for Disease Control and Prevention

Atlanta, GA

Elizabeth Mansfield, Ph.D.

Senior Policy Advisor

Food and Drug Administration

Rockville, MD

Roberta A. Pagon, M.D.

Professor of Pediatrics

Principal Investigator and Editor, GeneTests

University of Washington

Seattle, WA

Jeffrey Roche, M.D., M.P.H.

Medical Officer

Centers for Medicare & Medicaid Services

Baltimore, MD

Wayne A. Rosenkrans, Jr., Ph.D.

Chairman & President

Personalized Medicine Coalition

Washington, DC

David Samson, M.S.

Associate Director

Technology Evaluation Center

Blue Cross & Blue Shield Association

Chicago, IL

Fay Shamanski, Ph.D.

Assistant Director, Public Health and Scientific Affairs

College of American Pathologists

Washington, DC

Harold Sox, Ph.D.

Adjunct Professor of Medicine

Dartmouth College

Hanover, NH

Lee Steingisser, M.D.

Medical Director

Blue Cross/Blue Shield of Massachusetts

Boston, MA

Steven M. Teutsch, M.D., M.P.H.

Chief Science Officer

Los Angeles County Department of Public Health

Los Angeles, CA

Thomas Trikalinos, M.D., Ph.D.

Assistant Director

Tufts-New England Medical Center EPC

Boston, MA

Louise Wideroff, Ph.D.

Health Scientist Administrator

National Institute on Drug Abuse

Bethesa, MD

Ann M. Willey, Ph.D., J.D.

Director, Office of Laboratory Policy & Planning

Wadsworth Center, New York State Department of Health

Albany, NY

Marc Williams, M.D., FAAP, FACMG

Director, Clinical Genetics Institute

Intermountain Healthcare

Salt Lake City, UT