# References and Included Studies

1 Secretary's Advisory Committee on Genetics, Health, and Society. U.S. system of oversight of genetic testing: a response to the charge of the Secretary of Health and Human Services. Washington, DC. Department of Health & Human Services. 2008. Available at: http://www4.od.nih.gov/oba/SACGHS/reports/SACGHS_oversight_report.pdf.
2 Sun F, Bruening W, Uhl S, et al. Quality, Regulation and Clinical Utility of Laboratory-Developed Molecular Tests, Technology Assessment Report (Prepared by ECRI Institute Evidence-based Practice Center under Contract No. 290-2007-1063 I). Rockville, MD. Agency for Healthcare Research and Quality. May. 2010. Available at: http://www.cms.gov/determinationprocess/downloads/id72TA.pdf.
3 Teutsch SM, Bradley LA, Palomaki GE, et al., on behalf of the EGAPP Working Group. The evaluation of genomic applications in practice and prevention (EGAPP) initiative: methods of the EGAPP Working Group. Genet Med. Jan. 2009;11(1):3-14. [pmid: 18813139].
4 Marchionni L, Wilson RF, Marinopoulos SS, et al. Impact of Gene Expression Profiling Tests on Breast Cancer Outcomes, Evidence Report/Technology Assessment No. 160 (Prepared by The Johns Hopkins University Evidence based Practice Center under contract No. 290-02-0018). Rockville, MD. Agency for Healthcare Research and Quality. January. 2008. AHRQ Publication No. 08-E002. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/brcancergene/brcangene.pdf.
5 Bradley LA, Palomaki GE, Dotson WD. Evidence Report/Technology Assessment. Can UGT1A1 Genotyping Reduce Morbidity and Mortality in Patients With Metastatic Colorectal Cancer Treated With Irinotecan? (Prepared by RTI International under Project No. 0208235.036). Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group. January. 2009. Available at: http://www.egappreviews.org/docs/topics_colorectal.pdf.
6 McClain MR, Palomaki GE, Piper M, et al. A rapid-ACCE review of CYP2C9 and VKORC1 alleles testing to inform warfarin dosing in adults at elevated risk for thrombotic events to avoid serious bleeding. Genet Med. Feb. 2008;10(2):89-98. [pmid: 18281915].
7 Seidenfeld J, Samson DJ, Rothenberg BM, et al. HER2 Testing to Manage Patients With Breast Cancer or Other Solid Tumors, Evidence Report/Technology Assessment No. 172 (Prepared by the Blue Cross and Blue Shield Association Technology Evaluation Center Evidence-based Practice Center under Contract No. 290-02-0026). Rockville, MD. Agency for Healthcare Quality and Research. November. 2009. AHRQ Publication No. 09-E001. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/her2/her2.pdf.
8 Matcher DB, Thakur ME, Grossman I, et al. Testing for Cytochrome P450 Polymorphisms in Adults With Non-Psychotic Depression Treated With Selective Serotonin Reuptake Inhibitors (SSRIs), Evidence Report/Technology Assessment No. 146 (Prepared by the Duke Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. AHRQ Publication No. 07-E002. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/cyp450/cyp450.pdf.
9 Chen B, Gagnon M, Shahangian S, et al. Good laboratory practices for molecular genetic testing for heritable diseases and conditions. MMWR Recomm Rep. Jun. 12. 2009;58(RR-6):1-37. quiz CE-1–4. [pmid: 19521335].
10 Wilson JA, Zoccoli MA, Jacobson JW, et al. Verification and validation of multiplex nucleic acid assays; approved guideline [MM17-A]. Wayne, PA. Clinical and Laboratory Standards Institute (CLSI). 2008. Available at: http://www.clsi.org/source/orders/free/mm17-a.pdf.
11 International Organization for Standardization. International vocabulary of basic and general terms in metrology (VIM). Geneva. International Organization for Standardization. 2007.
12 International Organization for Standardization. ISO/IEC guide 2: standardization and related activities - general vocabulary. Geneva. International Organization for Standardization. 2004.
13 Current CLIA regulations (including all changes through 1/24/2004). Atlanta, GA. Centers for Disease Control and Prevention. Available at: http://wwwn.cdc.gov/clia/regs/toc.aspx. January 28, 2008.
14 Lijmer JG, Leeflang M, Bossuyt PM. Proposals for a Phased Evaluation of Medical Tests. Medical Tests–White Paper Series. Rockville, MD. Agency for Healthcare Research and Quality. November. 2009. http://www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid&=350. [pmid: 21290784].
15 Yerushalmy J. Statistical problems in assessing methods of medical diagnosis, with special reference to x-ray techniques. Public Health Rep. Oct. 4. 1947;62(39):1432-49. [pmid: 20340527].
16 Ledley RS, Lusted LB. Reasoning foundations of medical diagnosis. Science. Jul. 3. 1959;130(3366):9-21. [pmid: 1749340].
17 Swets JA. Measuring the accuracy of diagnostic systems. Science. Jun. 3. 1988;240(4857):1285-93. [pmid: 3287615].
18 Swets JA, Pickett RM. Evaluation of diagnostics systems - methods from signal detection theory. Introduction and chapter 1: fundamentals of accuracy analysis. New York. Academic Press. 1982:1-24.
19 Loop JW, Lusted LE. American College of Radiology Diagnostic Efficacy Studies. AJR Am J Roentgenol. Jul. 1978;131(1):173-9. [pmid: 97976].
20 Guyatt GH, Tugwell PX, Feeny DH, et al. A framework for clinical evaluation of diagnostic technologies. CMAJ. Mar. 15. 1986;134(6):587-94. [pmid: 3512062].
21 Fryback DG, Thornbury JR. The efficacy of diagnostic imaging. Med Decis Making. Apr-Jun. 1991;11(2):88-94. [pmid: 1907710].
22 Kent DL, Larson EB. Disease, level of impact, and quality of research methods. Three dimensions of clinical efficacy assessment applied to magnetic resonance imaging. Invest Radiol. Mar. 1992;27(3):245-54. [pmid: 1551777].
23 van der Schouw YT, Verbeek AL, Ruijs SH. Guidelines for the assessment of new diagnostic tests. Invest Radiol. Jun. 1995;30(6):334-40. [pmid: 7490184].
24 Pearl WS. A hierarchical outcomes approach to test assessment. Ann Emerg Med. Jan. 1999;33(1):77-84. [pmid: 9867891].
25 Zweig MH, Robertson EA. Why we need better test evaluations. Clin Chem. Jun. 1982;28(6):1272-6. [pmid: 7074932].
26 Freedman LS. Evaluating and comparing imaging techniques: a review and classification of study designs. Br J Radiol. Nov. 1987;60(719):1071-81. [pmid: 3318997].
27 Taylor CR, Elmore JG, Sun K, et al. Technology assessment in diagnostic imaging. A proposal for a phased approach to evaluating radiology research. Invest Radiol. Feb. 1993;28(2):155-61. [pmid: 8444573].
28 Pepe MS. Evaluating technologies for classification and prediction in medicine. Stat Med. Dec. 30. 2005;24(24):3687-96. [pmid: 16320261].
29 Gatsonis C. Design of evaluations of imaging technologies: development of a paradigm. Acad Radiol. Sep. 2000;7(9):681-3. [pmid: 10987328].
30 Sunshine JH, McNeil BJ. Rapid method for rigorous assessment of radiologic imaging technologies. Radiology. Feb. 1997;202(2):549-57. [pmid: 9015089].
31 Houn F, Bright RA, Bushar HF, et al. Study design in the evaluation of breast cancer imaging technologies. Acad Radiol. Sep. 2000;7(9):684-92. [pmid: 10987329].
32 Jarvik JG. Study design for the new millennium: changing how we perform research and practice medicine, Radiology. Mar. 1. 2002;222(3):593-4. Available at: http://radiology.rsnajnls.org/cgi/reprint/222/3/593. [pmid: 11867770].
33 Hunink MG, Krestin GP. Study design for concurrent development, assessment, and implementation of new diagnostic imaging technology, Radiology. Mar. 1. 2002;222(3):604-14. Available at: http://radiology.rsnajnls.org/cgi/reprint/222/3/604. [pmid: 11867773].
34 Sackett DL, Hatnes RB. Evidence base of clinical diagnosis The architecture of diagnostic research, BMJ Online. Mar. 2. 539. 2002:324-41. Available at: http://www.bmj.com.
35 Lumbreras B, Porta M, Marquez S, et al. QUADOMICS: An adaptation of the Quality Assessment of Diagnostic Accuracy Assessment (QUADAS) for the evaluation of the methodological quality of studies on the diagnostic accuracy of ‘-omics’-based technologies. Clin Biochem. Nov. 2008;41(16–17):1316-25. [pmid: 18652812].
36 Agency for Healthcare Research and Quality. U.S. Preventive Services Task Force procedure manual. Rockville, MD. Agency for Healthcare Research and Quality. July. 2008.
37 ACCE model system for collecting, analyzing and disseminating information on genetic tests. Atlanta, GA. Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/fbr.htm. May 3, 2007.
38 ACCE model system for collecting, analyzing and disseminating information on genetic tests. Atlanta, GA. Centers for Disease Control and Prevention. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm. January 6, 2010.
39 Methods Work Group, U.S. Preventive Services Task Force. Current methods of the U.S. Preventive Services Task Force: a review of the process. Rockville, MD. Agency for Healthcare Research and Quality. 2001. Available at: http://www.ahrq.gov/clinic/ajpmsuppl/review.pdf.
40 Segal JB, Brotman DJ, Emadi A, et al. Outcomes of Genetic Testing in Adults With a History of Venous Thromboembolism, Evidence Report/Technology Assessment No. 180 (Prepared by Johns Hopkins University Evidence-based Practice Center under Contract No. 290-2007-100610-I). Rockville, MD. Agency for Healthcare Research and Quality. June. 2009. AHRQ Publication No. 09-E011. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/factorvleiden/fvl.pdf.
41 Bonis PA, Trikalinos TA, Chung M, et al. Hereditary Nonpolyposis Colorectal Cancer: Diagnostic Strategies and Their Implications, Evidence Report/Technology Assessment No. 150 (Prepared by Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. May. 2007. AHRQ Publication No. 07-E008. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/hnpcc/hnpcc.pdf.
42 AACE draft genetic test review: cystic fibrosis. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm.
43 AACE draft genetic test review: Hemochromatosis. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm.
44 AACE draft genetic test review: venous thromboembolism. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm.
45 AACE draft genetic test review: breast & ovarian cancer. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm.
46 AACE draft genetic test review: colorectal cancer. Atlanta, GA. Centers for Disease Control and Prevention. 2009. Available at: http://www.cdc.gov/genomics/gtesting/ACCE/FBR/index.htm.
47 Myers ER, Havrilesky LJ, Kulasingam SL, et al. Genomic Tests for Ovarian Cancer Detection and Management, Evidence Report/Technology Assessment No. 145 (Prepared by the Duke University Evidence-based Practice Center under Contract No. 290-02-0025). Rockville, MD. Agency for Healthcare Research and Quality. October. 2006. AHRQ Publication No. 07-E001. Available at: http://www.ahrq.gov/downloads/pub/evidence/pdf/genomicovc/genovc.pdf.
48 Nelson HD, Huffman LH, Fu R, et al. Genetic Risk Assessment and BRCA Mutation Testing for Breast and Ovarian Cancer Susceptibility: Evidence Synthesis, Evidence Synthesis No. 37 (Prepared by the Oregon Evidence-based Practice Center under Contract No. 290-02-0024). Rockville, MD. Agency for Healthcare Research and Quality. September. 2005. Available at: http://www.ahrq.gov/downloads/pub/prevent/pdfser/brcagensyn.pdf.
49 Paez A, Skiest D. Methicillin-resistant Staphylococcus aureus: From the Hospital to the Community. Curr Infect Dis Rep. Mar. 2008;10(1):14-21. [pmid: 18377810].
50 Raman G, Chew P, Trikalinos TA, et al. Genetic Tests for Non-Cancer Diseases/Conditions: A Horizon Scan, Technology Assessment Program (Prepared by the Tufts-New England Medical Center Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. August. 2007. Available at: http://www.cms.hhs.gov/determinationprocess/downloads/id49TA.pdf.
51 Raman G, Wallace B, Chung M, et al. Update on Genetic Tests for Non-Cancer Diseases/Conditions: A Horizon Scan [draft] (Prepared by Tufts Medical Center Evidence-based Practice Center under Contract No. 290-2007-10055I). Rockville, MD. Agency for Healthcare Research and Quality. December. 2009. Available at: http://www.ahrq.gov/clinic/ta/genetictests.pdf.
52 Palomaki GE, Bradley LA, Douglas MP, et al. Can UGT1A1 genotyping reduce morbidity and mortality in patients with metastatic colorectal cancer treated with irinotecan?. An evidence-based review Gen Med. Jan. 1. 2009;11(1):21-34. [pmid: 19125129].
53 Palomaki GE, McClain MR, Melillo S, et al. EGAPP supplementary evidence review: DNA testing strategies aimed at reducing morbidity and mortality from Lynch syndrome. Genet Med. Jan. 2009;11(1):42-65. [pmid: 19125127].
54 Raman G, Trikalinos TA, Zintzaras E, et al. Reviews of selected pharmacogenetic tests for non-cancer and cancer conditions [final report] (Prepared by the Tufts Evidence-based Practice Center under Contract No. 290-02-0022). Rockville, MD. Agency for Healthcare Research and Quality. November. 2008. Available at: http://www.cms.hhs.gov/determinationprocess/downloads/id61TA.pdf.
55 Meeting summary. Analytic validity of genetic and laboratory tests: workgroup meeting #1 Rockville, MD Agency for Healthcare Research and Quality 2009 May 13 10
56 Meeting summary. Analytic validity of genetic and laboratory tests: workgroup meeting #2 Rockville, MD Agency for Healthcare Research and Quality 2009 Nov 3 16
57 Federal Food, Drug, and Cosmetic Act (FD&C Act). Available at: http://www.fda.gov/opacom/laws/fdcact/fdctoc.htm. January 26, 2010.
58 The Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group. Draft evaluation frameworks for genetic tests [Power Point slideshow]. The Evaluation of Genomic Applications in Practice and Prevention (EGAPP). 2005.
59 Harris RP, Helfand M, Woolf SH, et al. Current methods of the U.S. Preventive Services Task Force. A review of the process. Am J Prev Med. Apr. 2001;20(3 Suppl):21-35. [pmid: 11306229].
60 Centers for Medicare & Medicaid Services. Clinical Laboratory Improvement Amendments: Overview. Baltimore, MD. Centers for Medicare & Medicaid Services. Available at: http://www.cms.hhs.gov/clia/. January 26, 2010.
61 Centers for Disease Control and Prevention. Newborn screening quality assurance program. Atlanta, GA. Centers for Disease Control and Prevention. 2010. Jan. 22. Available at: http://www.cdc.gov/labstandards/nsqap.htm. January 26, 2010.
62 Cochrane Collaboration. Glossary. Cochrane Library. Available at: http://www.cochrane.org/glossary/5. January 10, 2011.
63 Lohr KN, Carey TS. Assessing ‘best evidence’: issues in grading the quality of studies for systematic reviews. Jt Comm J Qual Improv. Sep. 1999;25(9):470-9. [pmid: 10481816].
64 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews. BMC Med Res Methodol. Nov. 10. 2003;3(25):1-42. [pmid: 12515580].
65 Agency for Healthcare Research and Quality. Methods guide for medical test reviews [draft]. Rockville, MD. Agency for Healthcare Research and Quality. November. 2010. Available at: http://www.effectivehealthcare.ahrq.gov/tasks/sites/ehc/assets/File/methods_guide_for_medical_tests.pdf.
66 Atkins D, Best D, Briss PA, et al. Grading quality of evidence and strength of recommendations, BMJ. Jun. 19. 2004;328(7454):1490. Available at: http://bmj.bmjjournals.com/cgi/reprint/328/7454/1490. [pmid: 15205295].
67 West S, King V, Carey TS, et al. Systems to Rate the Strength of Scientific Evidence, Evidence Report/Technology Assessment No. 47 (Prepared by Research Triangle Institute - University of North Carolina Evidence-based Practice Center under Contract no. 290-97-0011). Rockville MD. Agency for Healthcare Research and Quality. April. 2002. AHRQ Publication No. 02-E016. Available at: http://www.ncbi.nlm.nih.gov/books/NBK33881/.
68 Whiting P, Rutjes AW, Dinnes J, et al. Development and validation of methods for assessing the quality of diagnostic accuracy studies. Health Technol Assess. Jun. 2004;8(25):iii-79. [pmid: 15193208].
69 Standards for the Reporting of Diagnostic accuracy studies (STARD). STARD checklist for the reporting of studies of diagnostic accuracy. Amsterdam. Standards for the Reporting of Diagnostic accuracy studies (STARD). Available at: http://www.stard-statement.org/pdf%20and%20word%20documents/Checklist.PDF. January 11, 2010.
70 McShane LM, Altman DG, Sauerbrei W, et al. Statistics Subcommittee of the NCI-EORTC Working Group on Cancer Diagnostics. Reporting recommendations for tumor MARKer prognostic studies (REMARK), Nature Clin Pract Urol. Aug. 2005;2(8):416-22. Available at: http://www.nature.com/nrclinonc/journal/v2/n8/pdf/ncponc0252.pdf. [pmid: 16482653].
71 Little J, Bradley L, Bray MS, et al. Reporting, appraising, and integrating data on genotype prevalence and gene-disease associations, Am J Epidemiol. Aug. 15. 2002;156(4):300-10. Available at: http://www.cdc.gov/genomics/hugenet/file/print/genedata.pdf. [pmid: 12181099].
72 Wells GA, Shea B, O'Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. Ottawa, ON. Ottawa Health Research Institute. Available: http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm. May 11, 2006.
73 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force (USPSTF) procedure manual, Appendix VII, criteria for assessing internal validity of individual studies. Rockville, MD. Agency for Healthcare Research and Quality. 1999. AHRQ Publication No. 08-05118-EF. Available at: http://www.ahrq.gov/clinic/uspstf08/methods/procmanualap7.htm.
74 U.S. Preventive Services Task Force (USPSTF). U.S. Preventive Services Task Force (USPSTF) procedure manual, Appendix VIII, criteria for assessing external validity (generalizability) of individual studies. Rockville, MD. Agency for Healthcare Research and Quality. 2008. Available at: http://www.ahrq.gov/clinic/uspstf08/methods/procmanualap8.htm.
75 Draft guidance for industry and FDA staff: Nucleic Acid Based In Vitro Diagnostic Devices for Detection of Microbial Pathogens (Draft). Rockville MD. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health. 2005. Dec. 8. Available at: http://www.fda.gov/cdrh/oivd/guidance/1560.pdf.
76 U.S. Food and Drug Administration, Center for Devices and Radiological Health. Guidance for industry and FDA staff. Pharmacogenetic tests and genetic tests for heritable markers. Rockville, MD. U.S. Food and Drug Administration, Center for Devices and Radiological Health. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm077862.htm.
77 Center for Biologics Evaluation and Research, Office of In Vitro Diagnostic Device Evaluation and Safety, Center for Devices and Radiological Health. In vitro diagnostic multivariate index assays. Draft guidance for industry, clinical laboratories, and FDA staff [Docket # 2006D-0347]. Rockville, MD. Center for Biologics Evaluation and Research. Jul. 26. 2007:15.
78 State of New York Department of Health. Checklist for genetic testing validation packages. Albany, NY. State of New York Department of Health. Apr. 30. 2009:3.
79 Whiting P, Rutjes AW, Reitsma JB, et al. The development of QUADAS: a tool for the quality assessment of studies of diagnostic accuracy included in systematic reviews, BMC Med Res Methodol. Nov. 10. 2003;3(1):25. Available at: http://www.biomedcentral.com/content/pdf/1471-2288-3-25.pdf. [pmid: 14606960].
80 Bast RC Jr, Feeney M, Lazarus H, et al. Reactivity of a monoclonal antibody with human ovarian carcinoma. J Clin Invest. Nov. 1981;68(5):1331-7. [pmid: 7028788].
81 Kobayashi H, Tamura M, Satoh T, et al. Clinical evaluation of new cancer-associated antigen CA125 II in epithelial ovarian cancers: comparison with CA125. Clin Biochem. Jun. 1993;26(3):213-19. [pmid: 8330391].
82 bioMerieux, Inc. 510(k) summary for VIDAS CA 125 II assay. K080561. Rockville, MD. U.S. Food and Drug Administration. 2008. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf8/K080561.pdf.
83 Tso E, Elson P, Vanlente F, et al. The “real-life” variability of CA-125 in ovarian cancer patients. Gynecol Oncol. Oct. 2006;103(1):141-4. [pmid: 16537090].
84 Kenemans P, Verstraeten AA, van Kamp GJ, et al. The second generation CA 125 assays. Ann Med. Feb. 1995;27(1):107-13. [pmid: 7741988].
85 Tamakoshi K, Kikkawa F, Shibata K, et al. Clinical value of CA125, CA19-9, CEA, CA72-4, and TPA in borderline ovarian tumor. Gynecol Oncol. Jul. 1996;62(1):67-72. [pmid: 8690294].
86 Mongia SK, Rawlins ML, Owen WE, et al. Performance characteristics of seven automated CA 125 assays. Am J Clin Pathol. Jun. 2006;125(6):921-7. [pmid: 16690492].
87 Davelaar EM, Schutter EM, Von Mensdorff-Pouilly S, et al. Clinical and technical evaluation of the ACS:OV serum assay and comparison with three other CA125-detecting assays. Ann Clin Biochem. Nov. 2003;40(6):663-73. [pmid: 14629806].
88 Clement M, Bischof P, Gruffat C, et al. Clinical validation of the new ELSA-CA 125 II assay: report of a European multicentre evaluation. Int J Cancer. Jan. 17. 1995;60(2):199-203. [pmid: 7829216].
89 Fisken J, Leonard RC, Roulston JE. Immunoassay of CA125 in ovarian cancer: A comparison of three assays for use in diagnosis and monitoring. Dis Markers. 1989;7(1):61-7. [pmid: 2653700].
90 Shelley MD, Fish RG. Evaluation of an immunoradiometric assay for the detection of an ovarian tumour marker, CA125, in serum. Ann Clin Biochem. May. 1986;23(Pt 3):292-6. [pmid: 3466568].
91 FDA News, FDA approves updated Warfarin (Coumadin) prescribing information. New genetic information may help providers improve initial dosing estimates of the anticoagulant for individual patients. Seattle, WA. Genelex Corporation. Available at: http://www.fda.gov/bbs/topics/NEWS/2007/NEW01684.html. December 6, 2007.
92 Evaluation of Genomic Applications in Practice and Prevention (EGAPP) Working Group. Recommendations from the EGAPP Working Group: testing for cytochrome P450 polymorphisms in adults with nonpsychotic depression treated with selective serotonin reuptake inhibitors. Genet Med. Dec. 2007;9(12):819-25. [pmid: 18091431].
93 Pauletti G, Godolphin W, Press MF, et al. Detection and quantitation of HER-2/neu gene amplification in human breast cancer archival material using fluorescence in situ hybridization. Oncogene. Jul. 4. 1996;13(1):63-72. [pmid: 8700555].
94 Middleton LP, Price KM, Puig P, et al. Implementation of America. Arch Pathol Lab Med. May. 2009;133(5):775-80. [pmid: 19415952].
95 Rubin I, Yarden Y. The basic biology of HER2. Ann Oncol. 2001;12(Suppl 1):S3-S8. [pmid: 11521719].
96 Yarden Y. Biology of HER2 and its importance in breast cancer. Oncology. 2001;61(Suppl 2):1-13. [pmid: 11694782].
97 Wolff AC, Hammond ME, Schwartz JN, et al. American Society of Clinical Oncology/College of American Pathologists guideline recommendations for human epidermal growth factor receptor 2 testing in breast cancer. Arch Pathol Lab Med. 2007;131(1):18-43. [pmid: 19548375].
98 Chen C, Peng J, Xia HS, et al. Quantum dots-based immunofluorescence technology for the quantitative determination of HER2 expression in breast cancer. Biomaterials. May. 2009;30(15):2912-18. [pmid: 19251316].
99 Moelans CB, de Weger RA, Ezendam C, et al. HER-2/neu amplification testing in breast cancer by Multiplex Ligation-dependent Probe Amplification: Influence of manual- and laser microdissection. BMC Cancer. Jan. 5. 2009;9:4. [pmid: 19123950].
100 Rosa FE, Silveira SM, Silveira CGT, et al. Quantitative real-time RT-PCR and chromogenic in situ hybridization: Precise methods to detect HER-2 status in breast carcinoma. BMC Cancer. Mar. 23. 2009;9:90. [pmid: 19309522].
101 Egervari K, Toth J, Nemes Z, et al. An alternative and reliable real-time quantitative PCR method to determine HER2/neu amplification in breast cancer. Appl Immunohistochem Mol Morphol. May. 2009;17(3):247-54. [pmid: 19098680].
102 Francis GD, Jones MA, Beadle GF, et al. Bright-field in situ hybridization for HER2 gene amplification in breast cancer using tissue microarrays: correlation between chromogenic (CISH) and automated silver-enhanced (SISH) methods with patient outcome. Diagn Mol Pathol. Jun. 2009;18(2):88-95. [pmid: 19430296].
103 Giltnane JM, Molinaro A, Cheng H, et al. Comparison of quantitative immunofluorescence with conventional methods for HER2/neu testing with respect to response to trastuzumab therapy in metastatic breast cancer. Arch Pathol Lab Med. Oct. 2008;132(10):1635-47. [pmid: 18834223].
104 Egervari K, Szollosi Z, Nemes Z. Immunohistochemical antibodies in breast cancer HER2 diagnostics. A comparative immunohistochemical and fluorescence in situ hybridization study. Tumour Biol. 2008;29(1):18-27. [pmid: 18497545].
105 Lourenco HM, Pereira TP, Fonseca RR, et al. HER2/neu detection by immunohistochemistry: optimization of in-house protocols. Appl Immunohistochem Mol Morphol. Mar. 2009;17(2):151-7. [pmid: 18971784].
106 Hofmann M, Stoss O, Gaiser T, et al. Central HER2 IHC and FISH analysis in a trastuzumab (Herceptin) phase II monotherapy study: assessment of test sensitivity and impact of chromosome 17 polysomy. J Clin Pathol. Jan. 2008;61(1):89-94. [pmid: 17412870].
107 O'Malley FP, Thomson T, Julian J, et al. HER2 testing in a population-based study of patients with metastatic breast cancer treated with trastuzumab. Arch Pathol Lab Med. Jan. 2008;132(1):61-5. [pmid: 18181675].
108 Kammori M, Kurabayashi R, Kashio M, et al. Prognostic utility of fluorescence in situ hybridization for determining HER2 gene amplification in breast cancer. Oncol Rep (Athens). Mar. 2008;19(3):651-6. [pmid: 18288397].
109 Masmoudi H, Hewitt SM, Petrick N, et al. Automated quantitative assessment of HER-2/neu immunohistochemical expression in breast cancer. IEEE Trans Med Imaging. Jun. 2009;28(6):916-25. [pmid: 19164073].
110 Theodosiou Z, Kasampalidis IN, Karayannopoulou G, et al. Evaluation of FISH image analysis system on assessing HER2 amplification in breast carcinoma cases. Breast. Feb. 2008;17(1):80-4. [pmid: 17889539].
111 Xiao Y, Gao X, Maragh S, et al. Cell lines as candidate reference materials for quality control of ERBB2 amplification and expression assays in breast cancer. Clin Chem. Jul. 1. 2009;55(7):1307-15. [pmid: 19443566].
112 AHRQ guidance for the evaluation of medical tests [draft]. Rockville, MD. Agency for Healthcare Research and Quality. December. 2009.
113 FDA/CDRH Public Meeting: Oversight of Laboratory Developed Tests (LDTs), date July 19-20, 2010. Rockville, MD. Food and Drug Administration. Available at: http://www.fda.gov/MedicalDevices/NewsEvents/WorkshopsConferences/ucm212830.htm. September 20, 2010.
114 U.S. National Library of Medicine, National Institutes of Health. Genetic testing registry. U.S. National Library of Medicine, National Institutes of Health. Available at: http://www.ncbi.nlm.nih.gov/gtr/. September 20, 2010.
115 Levin B. Molecular screening testing for colorectal cancer, Clin Cancer Res. Sep. 1. 2006;12(17):5014-5017. Available at: http://clincancerres.aacrjournals.org/content/12/17/5014.long. [pmid: 16951215].
116 Abruzzo LV, Barron LL, Anderson K, et al. Identification and validation of biomarkers of IgV(H) mutation status in chronic lymphocytic leukemia using microfluidics quantitative real-time polymerase chain reaction technology, J Mol Diagn. Sep. 2007;9(4):546-55. Available at: http://jmd.amjpathol.org/cgi/reprint/9/4/546. [pmid: 17690214].
117 Stoppler M. CA 125. New York, NY. WebMD. Available at: http://www.medicinenet.com/script/main/art.asp?articlekey=8099. January 28, 2010.
118 Paynter NP, Chasman DI, Buring JE, et al. Cardiovascular disease risk prediction with and without knowledge of genetic variation at chromosome 9p21.3, Ann Intern Med. Jan. 20. 2009;150(2):65-72. Available at: http://www.ncbi.nlm.nih.gov/pmc/articles/PMC2629586/pdf/nihms-75716.pdf. [pmid: 19153409].