# Peer Reviewers

Patrick M.M. Bossuyt, Ph.D.

Professor of Clinical Epidemiology

University of Amsterdam

Amsterdam, The Netherlands

Michele Caggana, Sc.D.

Deputy Director, Division of Genetics

Wadsworth Center, New York State Department of Health

Albany, NY

Bin Chen, Ph.D., FACMG

Geneticist/Health Scientist

Centers for Disease Control and Prevention

Atlanta, GA

Constantine A. Gatsonis, Ph.D.

Professor of Medical Science

Director, Center for Statistical Sciences

Acting Head, Biostatistics Section, Department of Community Health

Brown University

Providence, RI