# Methods

The topic of this project was initiated by the Agency for Healthcare Research and Quality (AHRQ) with input from experts and stakeholders with an interest in the evaluation of genetic tests. The main approach the ECRI Institute Evidence-based Practice Center (EPC) adopted to address the four Key Questions of the report was to assemble a panel of experts (referred to throughout the report as “the Workgroup”) to discuss the issues and build consensus on approaches to answering the Key Questions. These experts represent major stakeholders in the field of clinical testing (particularly genetic testing), and include pathologists, geneticists, clinical laboratory directors, diagnosticians, methodologists/biostatisticians, regulators, test developers, and academic researchers. The experts also represent a range of organizations and groups, including professional and medical societies (such as the College of American Pathologists), Federal agencies, payers, health plans, members of advisory committees (such as the Secretary's Advisory Committee on Genetics, Health, and Society), care providers, manufacturers, and technology assessment groups. International experts were also invited to serve on the Workgroup. A detailed list of the experts who participated on the panel is provided in the Acknowledgments section of this report. The Workgroup members served as sources of information, reviewed the preliminary findings of a targeted review performed by the ECRI Institute EPC team, reached consensus on key issues, and helped shape the draft report.

To facilitate discussions among the experts, the ECRI Institute EPC team performed a targeted literature review pertinent to evaluation frameworks, literature search strategies, quality-rating instruments, and testing variability for genetic testing. Given the extremely broad scope of the work, AHRQ and the ECRI Institute EPC team agreed that it would be important to be efficient in the targeted search and review. After consulting with AHRQ, we focused the search on published systematic and nonsystematic reviews in the relevant areas. We searched the major medical databases including MEDLINE, Embase, CINAHL, PsycINFO and the Cochrane Library. We also searched the Web sites of government agencies (e.g., AHRQ and Centers for Disease Control and Prevention) and technology assessment groups. Our search was further supplemented by information provided by experts during conference calls and in-person meetings.

For Key Question 1, existing frameworks for evaluating clinical tests were reviewed. With input from the Workgroup experts, we further narrowed the focus of the review on the evaluation frameworks used in completed evidence reports on genetic testing topics or developed from an initiative involving multiple stakeholders (such as the Evaluation of Genomic Applications in Practice and Prevention project and the Analytic validity; Clinical validity; Clinical utility; and Ethical, legal, and social implications project).

For Key Question 2, the targeted review focused on the search strategies for analytic validity data used in completed evidence reports. The utility of different search strategies, including various potential sources of unpublished data, were evaluated.

For Key Question 3, with input for the Workgroup experts, we focused the targeted review on the quality rating criteria for analytic validity studies that were used in completed evidence reports on genetic testing topics. Other relevant quality rating tools (e.g., key quality rating tools for diagnostic accuracy studies or for interventional studies) suggested by the Workgroup experts were also reviewed.

For Key Question 4, the targeted review was focused on reviews—systematic and non-systematic—on three sample genetic tests: Cytochrome p450 polymorphism testing, fluorescent in situ hybridization assays for ERBB2 (also called HER2/neu), and CA125 testing for ovarian cancer. The three sample tests were selected to represent three primary categories of testing: molecular tests, cytogenetic tests, and biochemical tests. Potential contributors to test result variability for the three tests were reviewed.

In addition to presenting the findings of the targeted review, the ECRI Institute EPC team also provided the experts with eight sample testing scenarios (e.g., diagnosis, prognostic evaluation, pharmacogenetic, screening for conditions caused by a germline mutation) to further facilitate discussions about evaluation frameworks. The provision of the sample scenarios was intended to facilitate a discussion among the Workgroup experts on evaluation frameworks designed around the intended use of a test.

The Workgroup was engaged throughout a series of meetings and teleconferences. Two face-to-face Workgroup meetings were held at AHRQ. The intent of the first meeting, held on May 13, 2009, was to obtain expert input on the key issues regarding the four objectives of the report and to review the findings of the targeted review performed by the project team. The second meeting was held on November 3, 2009. The purpose of this meeting was to build consensus on adopting a framework or set of frameworks to be used by the various stakeholders, and proposing a quality rating scheme for genetic tests. Several teleconferences were held throughout the draft development phase to obtain expert input.

This report did not involve quantitative methods to address any of the four Key Questions. Additional detailed information about the approaches to addressing the Key Questions are described in each relevant part of the Results chapter of this report. This chapter is organized into two sections—the first related to frameworks (Key Question 1), and the second to analytic validity issues (Key Questions 2–4). For each topic, we present the results of the targeted searches, followed by a summary of the discussions during the Workgroup meetings, and finally, a summary of the research team's recommendations.