# Introduction

Genetic testing is a rapidly expanding area with many clinical applications. According to GeneTests (available at: http://www.genetests.org), as of January 20, 2010, more than 1,890 genetic tests have been developed, of which 1,626 are available for use in clinical settings. While the introduction of new genetic tests creates tremendous potential for improving patient care, it is essential to evaluate these tests thoroughly to ensure that they are accurate and lead to improved patient outcomes when used in clinical practice settings.

While the general principles for evaluating genetic tests are similar to those for evaluating other medical tests, there are differences in how the principles need to be applied and the degree to which certain issues are relevant. One of the challenges commonly encountered in evaluating diagnostic tests in general is the absence of direct evidence for the impact of the test results on health outcomes.1-3 Evaluators often need to develop a potential “chain of evidence” to connect the use of the test to clinically important health outcomes.3 Meanwhile, the testing context for genetic testing (e.g., the targeted population, intended use, claim, or purpose of a test) is often more complex than that of other clinical tests. Genetic tests have been used for a broad range of clinical applications: making diagnoses, determining risk or susceptibility in asymptomatic individuals, revealing prognostic information to guide clinical management and treatment, and predicting response to treatments or environmental factors such as diet, behavioral factors, and drugs. Evaluating the clinical impact of genetic tests under these different scenarios, particularly when the evaluation involves heritable conditions, requires use of appropriate evaluation frameworks to clarify key questions that need to be addressed and the type of evidence required to answer the questions.

However, systematic reviewers have not been consistent to date in the use of evaluation frameworks for studying the published evidence about the accuracy and utility of genetic tests (refer to Table 2 in the Methods chapter). Use of different frameworks may lead to inconsistent findings even when evaluating the same test. It was suggested that we clarify a set of evaluation frameworks that could be customized for different genetic testing scenarios while sharing the same basic principles. These frameworks could be used to improve the transparency of the evaluation process.

Another frequently encountered challenge in the assessment of genetic tests is the evaluation of analytic validity. This refers to the ability of a laboratory test to accurately and reliably measure the property or characteristic it is intended to measure (e.g., the presence of a gene mutation). When evaluating laboratory tests, many systematic reviewers have avoided evaluating analytic validity, due in part to the difficulty of obtaining published relevant information.

In evaluating a genetic test, the evaluation of analytic validity is often required as part of the effort to build the “chain of evidence.” As observed by the authors of several evidence reports and the technical experts who were invited for this report (see discussions in the Results chapter), the paucity of published data remains a major barrier to evaluating analytic validity.4-8This is particularly the case for systematic reviewers who traditionally rely primarily on published data for their evaluations. Adequate evaluation of analytic validity may require identification of gray literature, unpublished data, and other unconventional sources (e.g., regulatory agencies, test developers, professional societies). Meanwhile, the quality of the data identified from such sources needs to be adequately assessed. However, there are no established quality criteria developed specifically for analytic validity data, although some groups (e.g., the Evaluation of Genomic Applications in Practice and Prevention Working Group) have initiated efforts to develop such criteria.3

To address these issues that have been identified as important to evaluation of genetic tests, the Agency for Healthcare Research and Quality commissioned this report. It is intended to address the following objectives:

1. Assess the feasibility of modifying existing frameworks for evaluating genetic tests, and clarify a comprehensive set of evaluation frameworks for common genetic testing scenarios;
2. Assess the strengths and limitations of different approaches to literature searches (including gray literature) for evaluating the analytic validity of genetic tests, and recommend an optimal approach for performing systematic reviews;
3. Assess the feasibility of applying existing quality rating criteria for studies on screening and diagnostic tests to analytic validity studies/reports (obtained from both published and gray literature) of genetic tests, and clarify an optimal quality rating instrument for these studies/reports;
4. Identify existing gaps in evidence on sources and contributors of variability common to genetic tests, and recommend approaches that will lead to generating data to fill these gaps.

These four objectives fall into two categories: (1) evaluation frameworks, and (2) analytic validity. The first category (objective 1) encompasses analytic validity, clinical validity, clinical utility, and societal impact, whereas the second category (objectives 2, 3, and 4) only focuses on analytic validity. To avoid potential confusion, the Results chapter of the report is organized by these two categories.

## Key Concepts

Analytic validity refers to the ability of a laboratory test to accurately and reliably measure the properties or characteristic it is intended to measure (e.g., the presence of a gene mutation). Analytic validity is a function of many factors, such as analytic accuracy, precision, analytic sensitivity and specificity, reportable range of test results for the test system, reference range, or normal values.1,9 Some of these terms used in the discussion of analytic validity have been defined differently in various guidelines or references.9,10 The following are the most commonly used definitions of key analytic performance characteristics that regulatory agencies usually require testing laboratories to validate:1,2,9

- Analytic accuracy refers to the closeness of the agreement between the result of a measurement and a true value of the measurand.11
- Precision refers to the closeness of agreement between independent results of measurements obtained under stipulated conditions.12 Precision is commonly determined by assessing repeatability (i.e., closeness of agreement between independent test results for the same measurand under the same conditions) and reproducibility (i.e., closeness of agreement between independent test results for the same measurand under changed conditions).9
- Analytic sensitivity describes how effectively a test can detect all true positive specimens, as determined by a reference method.1 This term is used for tests that yield an either/or result rather than for those that yield a quantitative result.
- Analytic specificity is defined as the ability of a measurement procedure to measure solely the analyte of interest.11 Two important aspects of analytic specificity are prevention of interference by endogenous or exogenous substances other than the analyte of interest and cross-reactivity of the analytic system with substances other than the intended analyte of interest.
- Reportable range of test results is defined as the span of test result values over which the laboratory can establish or verify the accuracy of the instrument or test system measurement response.13
- Reference range (also known as reference interval or normal values) is the range of test values expected for a designated population of persons (e.g., 95% of persons that are presumed to be healthy [or normal]).13

These and other key concepts related to analytic validity are also defined in the Acronyms/ Abbreviations and Glossary sections of this report.

Clinical validity refers to the accuracy with which a test predicts the presence or absence of a clinical condition or predisposition. Clinical validity is usually described in terms of clinical sensitivity, clinical specificity, positive and negative predictive values, likelihood ratios, diagnostic odds ratios, and the area under a receiver operator characteristic curve. These values and their interpretation depend on the prevalence of the specific disorder, penetrance, and modifiers (gene or environmental).1,2 Definitions of these concepts are provided in the Acronyms/Abbreviations and Glossary sections of the report. Clinical utility refers to the usefulness of the test and the value of the information to medical practice. Clinical utility represents a balance between health-related benefits and the harms that can ensue from using the information provided by a test. Those benefits and harms may need to be considered at the individual, family, and societal levels.1

## Scope of the Report

The primary focus of the report is genetic tests, which we define using the definition of the Secretary's Advisory Committee on Genetics, Health, and Society:

A genetic or genomic test involves an analysis of human chromosomes, deoxyribonucleic acid, ribonucleic acid, genes, and/or gene products (e.g., enzymes and other types of proteins), which is predominately used to detect heritable or somatic mutations, genotypes, or phenotypes related to disease and health.1

We acknowledge that some stakeholders may define “genetic tests” differently, therefore further clarify the scope of the report in this section.

The following types of analytes being tested are within the scope of this report:

- Tests that target common analytes such as DNA, RNA, protein, lipids, metabolites, et cetera
- Tests for both acquired/somatic and germline/constitutional genetic variants.

The following types of test methods are within the scope of this report:

- Biochemical tests
- Molecular tests
- Cytogenetic or cytology tests (although these were not the major focus of the project)
- Physician-based pre-analytic procedures such as fine needle aspiration (within the scope only to the extent that the variations in these procedures affect the test results).

The following types of testing purposes or intended uses are within the scope of this report:

- Diagnostic tests (for patients with symptoms)
- Screening tests (for patients without symptoms for at high risk for a condition)
- Population-based screening tests (e.g., newborn screening)
- Risk/susceptibility assessment tests
- Tests for prognosis assessment (e.g., tests for cancer recurrence risk assessment)
- Carrier status tests
- Prenatal diagnostic tests
- Pharmacogenetic tests
- Test for treatment monitoring
- Tests related to evaluating the human immune response (such as tests for engraftment monitoring) or human leukocyte antigen (HLA) typing.

The following tests are outside the scope of this report:

- Tests related to infectious pathogens or other analyses of microbial genomes
- Tests that target exogenous analytes such as toxins and environmental chemicals
- Radiology and related imaging-based genetic tests.

## Key Research Questions

Based on the four objectives, we addressed the following four Key Questions:

- Key Question 1: Is it feasible to clarify a comprehensive framework or a set of frameworks for evaluating genetic tests?
- Key Question 2: What are the strengths and limitations of different approaches to literature searching to assess evidence on variability in genetic and laboratory testing? Is there an optimal approach to literature search?
- Key Question 3: Is it feasible to apply existing quality rating criteria to analytic validity studies on genetic tests? Is there an optimal quality rating instrument for these studies?
- Key Question 4: What are existing gaps in evidence on sources and contributors of variability common to all genetic tests, or to specific categories of genetic tests? What approaches will lead to generating data to fill these gaps?