# Glossary

The key terms used in this report are defined in this section. Unless otherwise specified, the definitions are from a report published by the Secretary's Advisory Committee on Genetics, Health, and Society in 2008, U.S. System of Oversight of Genetic Testing: A Response to the Charge of the Secretary of Health and Human Services,1 or the EPC draft report prepared by ECRI Institute, Quality, Regulation and Clinical Utility of Laboratory-developed Tests.2

Analytic accuracy: refers to the closeness of the agreement between the result of a measurement and a true value of the measurand.11
Assay linearity: is defined as the ability (within a given range) to provide results that are directly proportional to the concentration (amount) of the analyte in the test sample. Linearity of tests is established by testing a dilution series of a positive sample.
Analytic sensitivity: Analytic sensitivity describes how effectively a test can detect all true positive specimens, as determined by a reference method.1 As it is more often used, this term is used for tests that yield a qualitative result.
Analytic specificity: is defined as the ability of a measurement procedure to measure solely the analyte of interest.11 Two important aspects of analytic specificity are interference by endogenous or exogenous substances other than the analyte of interest and cross-reactivity of the analytic system with substances other than the intended analyte of interest.
Analytic validity: simply refers to how well a test performs in the laboratory—how well does the test measure the properties or characteristic it is intended to measure (e.g., a gene mutation)?
Clinical validity: (also known as diagnostic accuracy) refers to the accuracy with which a test predicts the presence or absence of a clinical condition or predisposition.
Clinical utility: refers to the usefulness of the test and the value of information to medical practice. If a test has utility, it means that the results of the test can be used to seek effective treatment or provide other concrete benefit.
Cross-reactivity: refers to the reaction that an assay may have with analytes other than the ones it is designed to measure.
Diagnostic accuracy: is also known as clinical validity (see definition of clinical validity).
Diagnostic sensitivity: refers to the probability of a positive test result when disease is present.
Diagnostic specificity: refers to the probability of a negative test result when disease is absent
Health outcomes: are symptoms and conditions that patients can feel or experience, such as visual impairment, pain, dyspnea, impaired functional status or quality of life, and death.36
Interference: may result from contamination, admixture, or presence of exogenous substances in samples, which can occur for a variety of reasons such as poor sampling, lack of sample stabilizer (where appropriate), cross-contamination during sample processing, inclusion of normal, nondiseased tissue with the diseased tissue of interest, tissue from a source additional to the desired sample (e.g., maternal cells obtained during fetal specimen collection), or failure to remove exogenous substances (e.g., anticoagulants used during blood collection, residual reagents used during sample processing).
Intermediate outcomes: are pathologic and physiologic measures that may precede or lead to health outcomes. For example, elevated blood cholesterol level is an intermediate outcome for coronary artery disease.36
Precision: is defined as the closeness of agreement between independent results of measurements obtained under stipulated conditions.12 Precision is commonly determined by assessing repeatability (also defined in this Glossary) and reproducibility (also defined in this Glossary).9
Recovery: as a term in the area of analytic validity, refers to the measurable increase in analyte concentration or activity in a sample after adding a known amount of that analyte to the sample.
Reference range: also known as reference interval or normal values, is the range of test values expected for a designated population of persons (e.g., 95% of persons that are presumed to be healthy [or normal]).13
Repeatability: replication of results when the assay is performed multiple times on a single specimen. Repeatability is also referred to as precision (in the term's narrow sense) when the test result is expressed quantitatively.
Reportable range of test results: is defined as the span of test result values over which the laboratory can establish or verify the accuracy of the instrument or test system measurement response.13
Reproducibility: refers to the closeness of agreement between independent results of measurements obtained with the same assay method when as many known variables as possible (e.g., operators, instruments, reagent lots, day of the week, sites/laboratories) are tested for their effect on the assay result.
Robustness: refers to the ability of a method to remain unaffected by small fluctuations in assay parameters; it is often assessed through interlaboratory comparison studies or by varying parameters such as temperature and relative humidity to determine the operating range of the method.
Traceability: refers to a property of the result of a measurement or the value of a standard whereby it can be related to stated references, usually national or international standards, through an unbroken chain of comparisons, all having stated uncertainties.
Uncertainty: refers to a parameter associated with the result of a measurement that characterizes the dispersion of the values that could reasonably be attributed to the measurand; it is a formal quantitative statement of the confidence in the result of an assay.