# Executive Summary

## Introduction

Genetic testing is a rapidly expanding area with many clinical applications. While the introduction of new genetic tests creates tremendous potential for improving patient care, it is essential to evaluate these tests thoroughly to ensure that they are accurate and lead to improved patient outcomes when used in clinical practice settings. While the general principles for evaluating genetic tests are similar to those for evaluating other clinical tests, there are differences in how the principles are applied and the degree to which certain issues are relevant. The context for genetic testing is often more complex than that of other clinical tests. Evaluating the clinical impact of genetic tests under a broad range of clinical scenarios, particularly when the evaluation involves heritable conditions, requires use of appropriate frameworks. To date, systematic reviewers have not been consistent in their approaches to evaluating genetic tests. Clarifying a set of analytic frameworks customized for different testing scenarios but sharing the same principles could be beneficial to the practice of genetic testing evaluation.

Another challenge in evaluating genetic tests is the assessment of analytic validity. Analytic validity refers to the ability of a laboratory test to accurately and reliably measure the properties or characteristics it is intended to measure (e.g., the presence of a gene mutation). Evaluation of a genetic test's analytic validity is often required as part of the effort to establish the aforementioned “chain of evidence.” The paucity of published data and a lack of an optimized search strategy for identifying data on analytic validity from gray literature remain a major barrier to evaluating analytic validity of genetic tests. Meanwhile, there is a lack of established quality assessment guidance for assessing analytic validity studies when they are identified.

To address these important issues related to genetic test evaluation, the Agency for Healthcare Research and Quality commissioned this report. The report addressed the following four Key Questions:

- Key Question 1: Is it feasible to clarify a comprehensive framework or a limited set of frameworks for evaluating genetic tests by modifying existing frameworks?
- Key Question 2: What are the strengths and limitations of different approaches to literature searching to assess evidence on variability in genetic and laboratory testing? Is there an optimal approach to literature search?
- Key Question 3: Is it feasible to apply existing quality rating criteria to analytic validity studies on genetic tests? Is there an optimal quality rating instrument for these studies?
- Key Question 4: What are existing gaps in evidence on sources and contributors of variability common to all genetic tests, or to specific categories of genetic tests? What approaches will lead to generating data to fill these gaps?

These four key questions fall into two categories that are intrinsically connected but different in scope: evaluation frameworks and analytic validity. The first category (Key Question 1) overarches all evaluation areas for genetic tests (e.g., analytic validity, clinical validity, clinical utility and societal impacts). In contrast, the second category (Key Questions 2, 3, and 4) only focuses on the analytic validity issues.

## Methods

The main approach to meeting these objectives was to organize an expert Workgroup to seek input and build consensus on key issues. These experts represented major stakeholders and were engaged through meetings and teleconferences. To facilitate the discussions among the experts, a targeted review of pertinent literature was performed to identify current literature search strategies, quality-rating schemas, and evaluation frameworks. The project used case studies of selected tests to focus discussion in the Workgroup. The Workgroup experts served as sources of information, reviewed the preliminary findings of the targeted review, reached consensus on key issues, and helped to shape the report. The judgment on whether it is feasible to clarify a set of evaluation frameworks or an instrument for assessing the quality of analytic validity studies was made based on the consensus of the Workgroup experts and the ECRI Institute research team (referred as “the research team” hereafter).

## Results

### Key Question 1 Is it Feasible to Clarify a Comprehensive Framework or a Set of Frameworks for Evaluating Genetic Tests?

To answer Key Question 1, we sequentially addressed the following tasks:

- Define evaluation frameworks
- Identify major evaluation frameworks already developed
- Identify the unique needs of different stakeholders for evaluation frameworks
- Determine whether it is feasible to clarify or develop a comprehensive framework or set of frameworks that would meet the needs of all stakeholders
- Determine whether it is feasible to clarify a comprehensive framework or a set of frameworks by modifying existing frameworks that would fit different testing scenarios (e.g., diagnosis, prognostic evaluation, screening for heritable conditions, and pharmacogenetics)

An evaluation (or “organizing”) framework for medical test assessment serves the purpose of clarifying the scope of the assessment and the types of evidence necessary for addressing various aspects of test performance and their consequences. Some evaluation frameworks (e.g., the Fryback-Thornbury hierarchy) only provide general conceptual guidance to the evaluators or reviewers. Analytic frameworks (e.g., the frameworks developed by the U.S. Preventive Services Task Force [USPSTF] and the Evaluation of Genomic Applications in Practice and Prevention [EGAPP] Working Group) provide additional detail for a set of key questions (e.g., the relevant populations, interventions, comparators, outcomes, time points, and settings) and present the evaluation process graphically. In this report, we primarily focused on analytic frameworks when we explored the feasibility of proposing a set of analytic frameworks for genetic tests. However, we also reviewed conceptually oriented evaluation frameworks since this type of framework provides conceptual foundations for practice-driven analytic frameworks.

Our targeted literature search identified multiple evaluation frameworks for medical tests. Four of these frameworks (i.e., the Analytic validity; Clinical validity; Clinical utility; and Ethical, legal, and social implications [ACCE] model, the Fryback-Thornbury hierarchy, the EGAPP frameworks, and the USPSTF frameworks) were used more frequently in recent evidence reports on genetic testing topics. We compared these four frameworks (see Figure 1 in the report) and found that all of them cover three common domains of medical test evaluation: analytic validity, clinical validity (i.e., the accuracy with which a test predicts the presence or absence of a clinical condition or predisposition), and clinical utility (i.e., the usefulness of the test and the value of the information to medical practice). The ACCE and the Fryback-Thornbury models cover an additional domain, societal impact.

The Workgroup expert members and the research team agreed that different types of stakeholders (e.g., patients, providers, payers, regulators, and test developers) may have different issues to address, thus needing different frameworks, in evaluating genetic tests. However, for each type of stakeholder, it is feasible to clarify a set of analytic frameworks for common genetic testing scenarios, including diagnosis, screening, prognosis assessment, treatment monitoring, pharmacogenetics, risk/susceptibility assessment, and testing involving germline mutations. We presented a set of frameworks from patients' perspectives by adapting the frameworks developed by the EGAPP project. This set of frameworks (Figures 2–8) covers several common testing scenarios, including diagnosis in symptomatic patients, disease screening in asymptomatic patients, prognosis assessment, treatment monitoring, drug selection (including pharmacogenetics), risk/susceptibility assessment, and testing for germline-mutation-related conditions.

These frameworks inherit the concept of “chain of evidence” from the EGAPP frameworks and include a graphical depiction of the relationship between the population, the test being evaluated, subsequent interventions, and outcomes (including intermediate outcomes, patient outcomes, and potential harms). Under the frameworks, an overarching question is asked first to address whether a single body of evidence exists that directly establishes the connection between the use of the genetic test and health outcomes. Since such direct evidence, particularly from RCTs, is rarely available, constructing a chain of evidence by addressing a series of key questions (i.e., the other key questions specified in the frameworks [Figures 2–8]) is commonly required for evaluating the clinical utility of the tests. This series of Key Questions evaluates analytic validity, clinical validity, medical or personal decisionmaking, and both the benefits and harms associated with the tests. Even when direct evidence exists for addressing the overarching question, this evidence could be weak in terms of quality and quantity, and it might still be necessary to construct a chain of evidence.

We tested the usability of the presented frameworks for seven real-world sample testing scenarios. We generated research questions for the sample tests using the frameworks (Appendix B). We further demonstrated the feasibility of clarifying a similar set of analytic frameworks from other stakeholders' perspectives (Figures 9 and 10) by modifying the frameworks presented from patients' perspectives. In evaluating genetic tests, stakeholders such as providers and payers may be concerned with additional issues such as the potential legal, ethical, operational, financial, and societal impact (including cost-effectiveness) of the test.

### Key Question 2 What are the Strengths and Limitations of Different Approaches to Literature Searching to Assess Evidence on Variability in Genetic Testing? Is There an Optimal Approach to Literature Search?

To address Key Question 2, we first performed a targeted review of the search strategies used in completed evidence reviews on genetic testing topics. Several reports addressed analytic validity issues (including variability in testing results). In searching for data to address these issues, these reports all used a search strategy that combined search of peer-reviewed literature with search of gray literature. However, the types of gray literature sources searched varied across the reports.

As observed by the authors of the reports, lack of published data remains a major challenge to evaluating analytic validity of genetic tests. Summarizing the input from the workgroup, the findings of the targeted review and ECRI Institute's previous experience, we recommend a comprehensive search strategy that includes search of both published and unpublished data sources. Particularly, we provided a summary of common sources of unpublished data for analytic validity (Table 4). Brief comments on the strengths and limitations of the resources are provided as well.

### Key Question 3 Is it Feasible to Apply Existing Quality Rating Criteria to Analytic Validity Studies on Genetic Tests? Is There an Optimal Quality Rating Instrument for These Studies?

To identify existing criteria for assessing the quality of analytic validity studies, we first searched multiple electronic databases of peer-reviewed publications and queried the workgroup for other relevant resources. Our search identified one set of criteria specifically designed to assess the quality of analytic validity studies (published by the EGAPP Working Group in 2008). However, as we discuss in this report, some technical issues with the EGAPP approach restrict its applicability. In addition, we performed a targeted review of the quality-rating criteria for analytic validity studies used in completed evidence reports on genetic testing topics. We found no consensus among the authors of these reports on what criteria should be used for judging the quality of analytic validity studies.

We further searched electronic databases and queried the Workgroup to identify existing instruments for assessing the quality of studies that evaluate diagnostic accuracy (or clinical validity) of medical tests or therapeutic interventions. We also searched for guidance documents used by regulatory agencies for evaluating laboratory tests and the guidelines or standards published by professional societies or the Clinical Laboratory Standards Institute for laboratory testing. The Workgroup and the research team together reviewed the study quality assessment tools or criteria identified in the targeted search and agreed that none of these tools or criteria could be considered optimal for assessing the quality of analytic validity studies, thus an improved tool for such assessment is needed.

Summarizing the quality assessment tools identified in the targeted search and incorporating the input from the Workgroup, the research team proposed a 17-item checklist (Table 7) for evaluating the quality of analytic studies. The checklist evaluates key study quality areas including internal validity, reporting quality, and other factors potentially causing bias. This checklist requires further testing, but provides a foundation for other researchers to develop tools for their evaluation purposes.

### Key Question 4 What are Existing Gaps in Evidence on Sources and Contributors of Variability Common to All Genetic Tests, or to Specific Categories of Genetic Tests? What Approaches Will Lead to Generating Data to Fill These Gaps?

To address this key question, we utilized three case studies on tests of different types to demonstrate the issues that test evaluators may experience when attempting to evaluate the analytic validity of tests. We also searched for literature (e.g., systematic reviews and evidence reports) that may discuss the evidence gap issues related to analytic validity of genetic testing.

As we experienced during the discussion of the case studies, and as many other systematic reviewers (e.g., the authors of the evidence reports reviewed for Key Question 2) have observed, there are still gaps in evidence for addressing analytic validity of genetic tests. These gaps exist due to multiple factors, particularly the difficulty in generating data for test validation (lack of suitable reference standards or controls) and barriers to accessing unpublished data. There is no single-dimension solution to fill these gaps. To facilitate generation of data on analytic validity, the research community, professional societies, and test developers need to have more collaboration in efforts such as increasing the availability of appropriately validated samples that can be used for test validation, developing effective reference methods, and building formal sample-splitting or -sharing programs. Meanwhile, as many Workgroup experts suggested, laboratories, research funders, test developers, regulatory agencies, and professional societies should play a more active role in developing the infrastructure that would make the data currently scattered at various locations more accessible.

## Conclusions

This study revealed that different stakeholders may need to address different issues, thus use different frameworks, in evaluating genetic tests. However, for each type of stakeholder, it is feasible to clarify a set of evaluation frameworks for common genetic testing scenarios. The study also revealed that comprehensive search of literature, particularly gray literature, is commonly required for evaluating the analytic validity of genetic testing. There is also a need for an improved instrument for assessing the quality of analytic validity studies identified. Currently, significant gaps exist in evidence on genetic testing variability. This study presented some tools and strategies for improving the quality, consistency and transparency of genetic testing evaluation practice. Future effort is required to test these tools and strategies and to fill the gaps in evidence on the analytic validity of genetic testing.