# Examples of Testing Scenarios

In this section, we present seven examples of testing scenarios that we used to pilot test the analytic frameworks presented in this report. We used these frameworks to generate research questions for the sample tests to ensure that these frameworks are useful in performing real-world evaluation tasks.

Table B1 A sample testing scenario: diagnosis in symptomatic patients

Sample test: Sample test: DNA testing for cystic fibrosis diagnosis Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: ACCE draft report: cystic fibrosis42 Population that the test(s) are intended for: Symptomatic patients who need to establish the diagnosis of cystic fibrosis. Note that DNA testing of CF mutations can be used for multiple clinical purposes (e.g., diagnosis in symptomatic patients, screening in asymptomatic individuals, and prenatal screening via carrier testing). In this sample testing scenario, we only focus on the application of DNA testing in patients with symptoms. For applications of DNA testing in other populations for other clinical purposes, separate evaluations should be performed using different proposed frameworks. Test(s) being evaluated: A wide variety of DNA methodologies are available for cystic fibrosis testing. In this sample testing scenario, we assume to evaluate any one of the methodologically unique DNA tests for cystic fibrosis. As noted before, DNA testing of CF mutations can be used for multiple clinical purposes In this sample testing scenario, we only focus on the application of DNA testing in patients with symptoms. Key research questions generated under the analytic framework (Figure 2):; 1. Overarching question: Does use of the DNA testing lead to improved health outcomes in cystic fibrosis patients compared to the standard-of-care diagnostic strategy?; 2. Does the DNA test being evaluated have adequate analytic validity?; 3. What is the diagnostic accuracy of the test? Is the diagnostic strategy using the DNA test more accurate than the standard-of-care diagnostic strategy in detecting the condition?; 4. Does use of the test have any impacts on treatment decision making by clinicians or patients?; 5. Does the treatment lead to improved intermediate outcomes in comparison with no treatment?; 6. Does the treatment lead to improved health outcomes in comparison with no treatment?; 7. Are there harms associated with the DNA testing? Does the testing cause more harms than alternative testing strategies?; 8. Are there harms associated with the treatment? Does the treatment cause more harms than alternative treatments?; Additional issues: Since cystic fibrosis gene mutations are germline mutations, the effectiveness or safety of the test in family members of test-positive individuals may also need to be evaluated, if that is a concern of the evaluator. Refer to page 40 for discussions about analytic frameworks for germline-mutation-related testing.

Table B2 A sample testing scenario: screening in asymptomatic patients

Sample test: Molecular testing of stool samples for colorectal cancer screening Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: a review article published in the journal of Clinical Cancer Research115 Population that the test(s) are intended for: Individuals who are ages ≥50 years Test(s) being evaluated: Molecular testing of stool samples for colorectal cancer screening Key research questions generated under the analytic framework (Figure 3):; 1. Does use of the test lead to improved health outcomes compared to the standard-of-care screening strategy or no screening?; 2. Does the test have adequate analytic validity?; 3. How accurate is the test for detecting colon cancer? Is the screening strategy using the test more accurate than the standard-of-care screening strategy for detecting colon cancer?; 4. Does use of the test have any impact on the decision making by clinicians or patients regarding early intervention for colon cancer?; 5. Does the early intervention lead to improved intermediate outcomes in comparison with no intervention?; 6. Does the early intervention lead to improved health outcomes in comparison with no intervention?; 7. Does the testing cause any harm? Does the testing cause more harms than alternative testing strategies?; 8. Does the early intervention cause any harm? Does the intervention cause more harms than alternative interventions?

Table B3 A sample testing scenario: prognosis assessment

Sample test: IgVH mutation analysis for prognosis for patients with chronic lymphocytic leukemia Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: refer to an article published in Journal of Molecular Diagnostics in 2007^116^ (available at: http://jmd.amjpathol.org/cgi/content/full/9/4/546) Population that the test(s) are intended for: Patients diagnosed with chronic lymphocytic leukemia Test(s) being evaluated: Multiple laboratory-developed tests are available for IgVH mutation analysis. In this sample testing scenario, we assume to evaluate one of laboratory-developed tests. Key research questions generated under the analytic framework (Figure 4):; 1. Overarching question: Does use of the test lead to improved health outcomes in patients diagnosed with chronic lymphocytic leukemia compared to use of other prognosis assessment methods or to not doing the assessment?; 2. Does the test have adequate analytic validity?; 3. How accurately do the test results predict prognostic outcomes in patients with chronic lymphocytic leukemia? Is the prognosis assessment strategy using the test more accurate than the standard-of-care assessment strategy in predicting future health outcomes for the patients?; 4. Does use of the test have any impact on disease-management decisions?; 5. Do the disease management decisions lead to improved intermediate outcomes?; 6. Do the disease-management decisions lead to improved health outcomes?; 7. Does the testing cause any harm? Does the testing cause more harms than alternative testing strategies?; 8. What harms does the disease management strategy chosen based on the testing result cause? Does the strategy cause more harms than alternative disease management strategies?

Table B4 A sample testing scenario: treatment monitoring

Sample test: CA-125 test for ovarian cancer monitoring Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: refer to an article published on Web site of MedicineNet117 Population that the test(s) are intended for: women with ovarian cancer (Note that CA-125 testing may also be used for monitoring other malignancy. But in this sample testing scenarios, we only focus on ovarian cancer.) Test(s) being evaluated: CA-125 analysis for ovarian cancer monitoring (Note that CA-125 testing may also be used for other clinical purposes. But in this sample testing scenario, we only focus on use of the test for ovarian cancer monitoring) Key research questions generated under the analytic framework (Figure 5):; 1. Overarching question: Does use of the test lead to improved health outcomes in women with ovarian cancer compared to use of the standard-of-care treatment monitoring strategy?; 2. Does the test have adequate analytic validity?; 3. How accurate is the test for indicating the effectiveness of the treatment? Is the treatment monitoring strategy using the test more accurate than the standard-of-car monitoring strategy in evaluating the effectiveness of the treatment?; 4. Do the testing results have impacts on disease management decisions (such as, opt for different treatments or adjustment of dosages)?; 5. Do the disease management decisions lead to improved intermediate outcomes?; 6. Do the disease management decisions lead to improved health outcomes?; 7. Are there harms associated with the testing? Does the testing cause more harms than alternative testing strategies?; 8. What harms does the disease management strategy chosen based on the testing result cause? Does the strategy cause more harms than alternative disease management strategies?

Table B5 A sample testing scenario: pharmacogenetics (sample 1)

Sample test scenario 1: Testing for cytochrome P450 polymorphism in adults with non-psychotic depression treated with selective serotonin reuptake inhibitors (SSRIs) Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: EPC report: Testing for Cytochrome P450 Polymorphisms in Adults With Non-Psychotic Depression Treated With Selective Serotonin Reuptake Inhibitors (SSRIs)8 Population that the test(s) are intended for: Adults entering selective serotonin reuptake inhibitor (SSRI) treatment for non-psychotic depression Test(s) being evaluated: clinically available CYP450 polymorphism tests Key research questions generated under the analytic framework (Figure 6):; 1. Overarching question: Does testing for cytochrome P450 (CYP450) polymorphism leads to improvement in health outcomes compared to not testing?; 2. Do clinically available CYP450 polymorphism tests have analytic validity?; 3. How accurate is the CYP450 polymorphism testing for predicting patients' response to SSRI?; 3a How well does CYP450 testing predict SSRI efficacy?; 3b How well does CYP450 testing predict SSRI-related adverse reactions?; 4. Does CYP450 testing influence treatment decisions by patients and providers?; 5. Do personalized treatment strategies based on CYP450 polymorphism testing results lead to improved intermediate outcomes compared to not testing?; 6. Do personalized treatment strategies based on CYP450 polymorphism testing results lead to improved health outcomes compared to not testing?; 7. Are there harms associated with any CYP450 polymorphism testing? Does the testing cause more harms than alternative testing strategies?; 8. Are there harms associated with the personalized treatment strategy that is based on CYP450 polymorphism testing results? Does the strategy cause more harms than alternative treatment strategies?

Table B6 A sample testing scenario: pharmacogenetics (sample 2)

Sample test scenario 2: ERBB2 testing with FISH assays for guiding trastuzumab treatment in patients with breast cancer Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: EPC report: HER2 Testing to Manage Patients with Breast Cancer or Other Solid Tumors7 Population that the test(s) are intended for: ERBB2 testing has been used to manage patients with breast, ovarian, lung, prostate, or head and neck tumors. In this sample testing scenario, we only focus on patients with breast cancer. For applications of ERBB2 testing in other populations, separate evaluations should be performed using the same or different frameworks. Test(s) being evaluated: There are several types of assays (e.g., FISH, IHC, etc.) that have been used to analyze ERBB2 status in tumor tissues. ERBB2 testing has also been used to guide trastuzumab treatment targeting the ERBB2 molecule; to guide selection of breast cancer treatments other than trastuzumab (i.e., chemotherapy regimen or hormonal therapy regimen); to monitor treatment response or disease progression in the patients. In this sample testing scenario, we only consider FISH assays for guiding trastuzumab treatment targeting the ERBB2 molecule. For applications of ERBB2 testing for other clinical purposes, separate evaluations should be performed using the same or different frameworks. Key research questions generated under the analytic framework (Figure 6):; 1. Overarching question: Does ERBB2 testing with FISH assays lead to improvement in health outcomes in patients with breast cancer compared to use of other tests or not testing at all?; 2. Do FISH assays for testing ERBB2 have analytic validity?; 3. How accurate are the FISH assays for predicting patients' response to trastuzumab?; 3a How well do the FISH assays predict trastuzumab efficacy?; 3b How well do the FISH assays predict trastuzumab -related adverse reactions?; 4. Does ERBB2 testing with FISH assays influence treatment decisions by patients and providers?; 5. Do personalized treatment strategies based on ERBB2 testing results lead to improved intermediate outcomes?; 6. Do personalized treatment strategies based on ERBB2 testing results lead to improved health outcomes?; 7. Are there harms associated with FISH assays for testing ERBB2? Does the testing cause more harms than alternative testing strategies?; 8. Are there harms associated with the personalized treatment strategy that is based on ERBB2 testing results? Does the strategy cause more harms than alternative treatment strategies?

Table B7 A sample testing scenario: risk/susceptibility assessment

Sample test: Testing for polymorphism in chromosome 9p21.3 for predicting risk of cardiovascular disease Recommended source of background information about the test(s), the biomarker being tested and the clinical condition: refer to a paper published in the Annals of Internal Medicine in 2009^118^ Population that the test(s) are intended for: the general population Test(s) being evaluated: In this sample testing scenario, we assume to evaluate an laboratory-developed test for analyzing polymorphism in chromosome 9p21.3 for predicting risk of cardiovascular disease Key research questions generated under the analytic framework (Figure 7):; 1. Overarching question: Does the testing improve overall health outcomes in the general population being screened compared to the standard-of-care strategy for predicting cardiovascular disease risk?; 2. Does the test have adequate analytic validity?; 3. How accurate is the test in predicting the likelihood of a patient to develop cardiovascular disease? Is the risk assessment strategy using the test more accurate than the standard-of-care strategy in making the prediction?; 4. Do the test results have impacts on clinical or personal decision making?; 5. Do the clinical or personal decisions lead to improved intermediate outcomes?; 6. Do the clinical or personal decisions lead to improved health outcomes?; 7. Are there harms associated with the testing? Does the testing cause more harms than alternative testing strategies?; 8. Do the clinical or personal decisions cause any harm? Does the action taken by the patient or clinician based on the testing result cause more harms than alternative actions?