# Methods of Identifying the Literature

## Part 1 Electronic Database Searches

The following databases have been searched for relevant information:

Name | Date limits | Platform/Provider
CINAHL | 1982 – February 6, 2009 | OVID
EMBASE (Excerpta Medica) | 1980 – January 15, 2010 | OVID
MEDLINE | 1950 – January 15, 2010 | OVID
PreMEDLINE | Searched January 15, 2010 | OVID

### Hand Searches of Journal and Nonjournal Literature

Journals and supplements maintained in ECRI Institute's collections were routinely reviewed. Nonjournal publications and conference proceedings from professional organizations, private agencies, and government agencies were also screened. Other mechanisms used to retrieve additional relevant information included review of bibliographies/reference lists from peer-reviewed and gray literature. (Gray literature consists of reports, studies, articles, and monographs produced by federal and local government agencies, private organizations, educational facilities, consulting firms, and corporations. These documents do not appear in the peer-reviewed journal literature.)

The search strategies employed combinations of freetext keywords as well as controlled vocabulary terms including (but not limited to) the following concepts. The strategy below is presented in Ovid syntax; the search was simultaneously conducted across Embase and MEDLINE. A parallel strategy was used to search the databases comprising the Cochrane Library.

Medical Subject Headings (MeSH), Emtree, and Keywords

[underlined: Conventions]:

OVID

$ | = | truncation character (wildcard)
exp | = | “explodes” controlled vocabulary term (e.g., expands search to all more specific related terms in the vocabulary's hierarchy)
/ | = | limit controlled vocabulary heading
.fs. | = | floating subheading
.hw. | = | limit to heading word
.md. | = | type of methodology (PsycINFO)
.mp. | = | combined search fields (default if no fields are specified)
.pt. | = | publication type
.ti. | = | limit to title
.tw. | = | limit to title and abstract fields

Topic-Specific Search Terms

Concept | Controlled Vocabulary | Keywords
Analytic validity | Accuracy/ Diagnostic accuracy/ exp Diagnostic error/ exp Diagnostic errors/ Precision/ exp Prediction and forecasting/ Predictive value of tests/ Receiver operating characteristic/ ROC curve/ Sensitivity and specificity/ | analytic validity false negative false positive likelihood true negative true positive
Breast cancer | Exp breast cancer/ Exp breast neoplasms | Breast cancer$ Breast carcinoma$ Breast neoplasm$ Breast tumor$ Breast tumour$
CA-125 | CA 125 antigen/ CA-125 antigen/ Tumor marker/ Tumor markers, biological/ | CA125 CA-125
Clinical chemistry | analysis Exp chemistry, analytic Exp clinical chemistry Exp clinical laboratory techniques/ Exp diagnosis, measurement/ Exp genetic procedures Exp genetic techniques/ Exp immunologic procedures/ Exp immunologic tests/ Exp immunoprecipitation/ Exp microchip analysis/ Exp microchip analytic procedures/ Exp molecular probe techniques/
FISH | Exp immunohistochemistry/ In situ hybridization, fluorescence | Autometallographic hybridization Bright field hybridization Chromogenic hybridization CISH FISH Fluorescence in situ hybridization Gold-facilitated hybridization Goldfish IHC immunocytochemistry immunohistochemistry
Frameworks | | REMARK Standards for reporting of diagnostic accuracy STARD Tumor marker utility grading system TMUGS
Frameworks | Checklist Methods.fs Models, theoretical Named inventories, questionnaires and rating scales Predictive value of tests Scoring system Sensitivity and specificity | Assess$ Checklist$ Criteria Framework$ Grading Measure Methodological Model$ Paradigm Quality Rating$ Reporting Scale$ Utility Validat$
HER2-Neu | Epidermal growth factor receptor 2 Epidermal growth factor receptor-neu.nm. Genes, erbB-2 Receptor, erbB-2 Receptor, epidermal growth factor | Epidermal growth factor receptor-2 erbB-2 erbB2 her-2$ her2$
Ovarian cancer | exp Carcinoma/ Genital neoplasms, female/ Neoplasms, glandular/ exp Ovarian neoplasms/ exp Ovary cancer/ Ovary metastasis/ Ovary tumor/ | adenoma$ cancer$ carcinom$ malig$ neoplas$ ovari$ ovary sarcoma$ tumor$ tumour$
Treatment response | exp Disease course/ exp Disease progression/ exp Prognosis/ exp Treatment outcome/ Follow-up studies/ Outcome assessment health care/ Outcome assessment/ Prognosis/ Time factors/ Treatment response/ | Monitor$ Prognos$ Respond$ Response Treatment

Frameworks for Gauging Analytic Validity

Embase/MEDLINE - English language, human, remove overlap

2000 – February 2009

Set Number | Concept | Search statement
1 | Clinical tests | Exp chemistry analytic/ or exp clinical laboratory techniques/ or exp genetic techniques/ or exp immunologic tests/ or exp immunoprecipitation/ or exp microchip analytic procedures/ or exp molecular probe techniques/
2 | | ((exp clinical chemistry/ or exp diagnosis, measurement/) and analysis/) or exp genetic procedures/ or exp immunologic procedures/ or exp microchip analysis/
3 | Combine sets | 1 or 2
4 | Analytic validity | (exp prediction and forecasting/ or (predictive value of tests or receiver operating characteristic or ROC curve or sensitivity and specificity or accuracy or diagnostic accuracy or precision or likelihood).de. or ((false or true) adj (positive or negative)))
5 | | Valid$.ti,ab.
6 | | ((intraobserver or intra-observer or interobserver or inter-observer or interpret$ or kappa or observer bias or observer variability or reader$ or reader concordance or reliab$ or repeatab$ or replicat$).tw. or observer variation.de.)
7 | Combine sets | 4 or 5 or 6
8 | Combine sets | 3 and 6
9 | Limit to systematic reviews | 8 and (research synthesis or (systematic review or meta analysis or meta-analysis).de. or ((evidence base$ or methodol$ or systematic or quantitative$ or studies).mp. and (review.de. or review.pt.)))
10 | Frameworks | 8 and ((model$ or framework$ or paradigm$).ti or models theoretical/)
11 | Refine | 10 and (9 or valid$.ti. or method$.ti. or mt.fs.)

Quality Rating Criteria for Studies on Clinical Tests

Embase/MEDLINE - English language, human, remove overlap

Database inception – February 2009

Set Number | Concept | Search statement
1 | Clinical tests | Exp chemistry analytic/ or exp clinical laboratory techniques/ or exp genetic techniques/ or exp immunologic tests/ or exp immunoprecipitation/ or exp microchip analytic procedures/ or exp molecular probe techniques/
2 | | ((exp clinical chemistry/ or exp diagnosis, measurement/) and analysis/) or exp genetic procedures/ or exp immunologic procedures/ or exp microchip analysis/
3 | Combine sets | 1 or 2
4 | Specific rating systems | Standards for reporting of diagnostic accuracy or STARD or tumor marker utility grading system or TMUGS or (“tumour marker prognostic studies” adj3 REMARK)
5 | Rating quality | ((quality or validat$ or utility) adj4 (assess$ or rating$ or grading or reporting or criteria or measure$ or methodological or checklist$ or scale$ or instrument$))
6 | | Rating scale/ or scoring system/ or checklist/ or named inventories, questionnaires and rating scales/ or *predictive value of tests/ or *sensitivity and specificity/
7 | Combine sets | 5 or 6
8 | Combine sets | 3 and 7
9 | Refine | 8 and ((level adj3 evidence) or accuracy or checklist or rating or grading or checklist$ or scale$ or instrument$).ti,ab.
10 | | 9 and (diagnostic or screening or laboratory or genetic or genomic or pharmacogenomic or marker$ or biomarker$).ti,ab.
11 | Eliminate overlap | 10 not 4
12 | Refine | 11 and ((methodologic or systematic$ or meta$ or laboratory or accuracy).ti. or review.pt. or evaluation studies.pt.)
13 | Combine sets | 4 or 12
14 | Eliminate overlap | Remove duplicates from 13

Case Study – CA-125

Embase/MEDLINE - English language, human, remove overlap

Database inception – July 2009

Set Number | Concept | Search statement
1 | CA125 | CA-125 antigen/ or Tumor markers, biological/ or CA 125 antigen/ or tumor marker/ or CA125 or CA-125
2 | Ovarian cancer | (ovari$ or ovary) and ((cancer$ or carcinom$ or tumour$ or tumor$ or neoplas$ or malig$ or sarcoma$ or adenoma$) or exp carcinoma/ or genital neoplasms, female/ or neoplasms, glandular)
3 | | Exp ovarian neoplasms/ or exp ovary cancer/ or ovary metastasis or ovary tumor
4 | Combine sets | 2 or 3
5 | Combine sets – CA125 and ovarian cancer | 1 and 4
6 | Treatment response | 5 and ((Treatment adj2 (response or respond$ or monitor$)).mp. or exp prognosis/ or exp treatment outcome/ or exp disease progression/ or exp disease course/ or treatment response/ or time factors/ or outcome assessment health care/ or outcome assessment/ or follow-up studies/ or prognosis/ or prognos$.tw.)
7 | Analytic validity | 6 and (analytic validity or receiver operating characteristic/ or ROC curve/ or sensitivity and specificity/ or accuracy/ or diagnostic accuracy/ or precision/ or exp prediction and forecasting/ or exp diagnostic errors/ or exp diagnostic error/ or likelihood or ((false or true) adj (positive or negative)) or predictive value of tests/)
8 | Limit by study type | 6 and (Randomized controlled trials/ or random allocation/ or double-blind method/ or single-blind method/ or placebos/ or cross-over studies/ or crossover procedure/ or cross over studies/ or double blind procedure/ or single blind procedure/ or placebo/ or latin square design/ or crossover design/ or double-blind studies/ or single-blind studies/ or triple-blind studies/ or random assignment/ or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis or follow-up studies/ or intermethod comparison/ or parallel design/ or control group/ or prospective study/ or retrospective study/ or case control study/ or major clinical study/ or evaluation studies/ or follow-up studies/ or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham)).mp. or latin square.mp. or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not NCT).mp.)
9 | Combine sets | 7 or 8
10 | Limit by publication type | 9 not (letter/ or editorial/ or news/ or comment/ or case reports/ or note/ or conference paper/ or review/ or (letter or editorial or news or comment or case reports or review).pt.)
11 | Eliminate overlap | Remove duplicates from 10
12 | Limit by concept | 11 and 8 and (*CA-125 antigen/ or *CA 125 antigen/ or (CA125 or CA-125).ti.)
13 | | 11 and 7
14 | Combine sets | 12 or 13

Case Study – p450 Polymorphisms and Depression

Embase/MEDLINE - English language, human, remove overlap

2006 - 2010

Set number | Concept | Search statement
1 | Cytochrome p450 polymorphisms | Cytochrome p-450 enzyme system/ or aryl hydrocarbon hydroxylases/ or cytochrome p-450 cyp2d6/ or cytochrome p450/
2 | | Cyp2c19 or cyp2c9 or cyp2cd6 or cyp2c19 or cyp2c9 or cyp2d6
3 | Combine sets | 1 or 2
4 | SSRIs | exp serotonin uptake inhibitors/ or exp serotonin uptake inhibitor/
5 | | Escitalopram or citalopram or fluoxetine or fluvoxamine or paroxetine or sertraline or celexa or lexapro or Prozac or luvox or paxil or zoloft
6 | Combine sets | 4 or 5
7 | Combine sets | 3 and 6
8 | | 7 and ((Treatment adj2 (response or respond$ or monitor$)).mp. or exp prognosis/ or exp treatment outcome/ or exp disease progression/ or exp disease course/ or treatment response/ or time factors/ or outcome assessment health care/ or outcome assessment/ or follow-up studies/ or prognosis/ or prognos$.tw.)
9 | | 8 and (analytic validity or receiver operating characteristic/ or ROC curve/ or sensitivity and specificity/ or accuracy/ or diagnostic accuracy/ or precision/ or exp prediction and forecasting/ or exp diagnostic errors/ or exp diagnostic error/ or likelihood or ((false or true) adj (positive or negative)) or predictive value of tests/)
10 | Limit by study type | 8 and (Randomized controlled trials/ or random allocation/ or double-blind method/ or single-blind method/ or placebos/ or cross-over studies/ or crossover procedure/ or cross over studies/ or double blind procedure/ or single blind procedure/ or placebo/ or latin square design/ or crossover design/ or double-blind studies/ or single-blind studies/ or triple-blind studies/ or random assignment/ or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis or follow-up studies/ or intermethod comparison/ or parallel design/ or control group/ or prospective study/ or retrospective study/ or case control study/ or major clinical study/ or evaluation studies/ or follow-up studies/ or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham)).mp. or latin square.mp. or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not NCT).mp.)
11 | Limit to major concept or title word | *1 or (1 or 6).ti.
12 | Combine sets | 10 and 11
13 | Combine sets | 9 or 12

Case Study – erbB-2 FISHEmbase/MEDLINE

English language, human, remove overlap

2007 - 2010

Set Number | Concept | Search statement
1 | HER2-Neu | Genes, erbB-2/ or receptor, erbB-2/ or receptor, epidermal growth factor/ or epidermal growth factor receptor-neu.nm. or epidermal growth factor receptor 2/ or (her-2$ or her2$ or erbB-2 or erbB2 or epidermal growth factor receptor-2).ti,ab.
2 | FISH | Exp Immunohistochemistry/ or in situ hybridization, fluorescence/ or (immunohistochemistry or immunocytochemistry or IHC or fluorescence in situ hybridization or fluorescence in-situ hybridization or FISH or (chromogenic and hybridization) or CISH or ((gold-facilitated or autometallographic or bright field) and hybridization) or goldfish).ti,ab.
3 | Breast cancer | Exp breast neoplasms/ or exp breast cancer/ or (breast and (neoplasm$ or cancer$ or carcinoma$ or tumor$ or tumour$).ti,ab.)
4 | Combine sets | 1 and 2 and 3
5 | Treatment response | 4 and ((Treatment adj2 (response or respond$ or monitor$)).mp. or exp prognosis/ or exp treatment outcome/ or exp disease progression/ or exp disease course/ or treatment response/ or time factors/ or outcome assessment health care/ or outcome assessment/ or follow-up studies/ or prognosis/ or prognos$.tw.)
6 | Analytic validity | 5 and (analytic validity or receiver operating characteristic/ or ROC curve/ or sensitivity and specificity/ or accuracy/ or diagnostic accuracy/ or precision/ or exp prediction and forecasting/ or exp diagnostic errors/ or exp diagnostic error/ or likelihood or ((false or true) adj (positive or negative)) or predictive value of tests/)
7 | Limit by study type | 5 and (Randomized controlled trials/ or random allocation/ or double-blind method/ or single-blind method/ or placebos/ or cross-over studies/ or crossover procedure/ or cross over studies/ or double blind procedure/ or single blind procedure/ or placebo/ or latin square design/ or crossover design/ or double-blind studies/ or single-blind studies/ or triple-blind studies/ or random assignment/ or exp controlled study/ or exp clinical trial/ or exp comparative study/ or cohort analysis or follow-up studies/ or intermethod comparison/ or parallel design/ or control group/ or prospective study/ or retrospective study/ or case control study/ or major clinical study/ or evaluation studies/ or follow-up studies/ or random$.hw. or random$.ti. or placebo$.mp. or ((singl$ or doubl$ or tripl$ or trebl$) and (dummy or blind or sham)).mp. or latin square.mp. or ISRCTN$.mp. or ACTRN$.mp. or (NCT$ not NCT).mp.)
8 | Combine sets | 6 or 7
9 | Limit by publication type | 8 not (letter/ or editorial/ or news/ or comment/ or case reports/ or note/ or conference paper/ or review/ or (letter or editorial or news or comment or case reports or review).pt.)
10 | Eliminate overlap | Remove duplicates from 9
11 | Limit to major concept | *2
12 | Limit to title word | 2.ti
13 | Combine sets | 10 and (11 or 12)

## Part 2 Gray Literature Searches

### Case Study – CA-125

Google Search String:

(CA125 OR “CA-125” OR “CA 125”) (ovary OR ovarian) (sensitivity OR specificity OR precision)

(CA125 OR “CA-125” OR “CA 125”) (ovary OR ovarian) “analytic validity”

(CA125 OR “CA-125” OR “CA 125”) dissertation (validity OR sensitivity OR specificity OR accuracy OR precision OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “hook effect” OR linearity)

(CA125 OR “CA-125” OR “CA 125”) assay (validity OR sensitivity OR specificity OR accuracy OR precision OR “false positive” OR “false negative” OR “true positive” OR “true negative” OR “hook effect” OR linearity)

Sample retrieval – the following links were active as of 1/27/2010

#### Patents

US Patent 4921790 - Tumor specific assay for CA125 ovarian cancer antigen

The references might be useful but the actual patent description is not likely to be useful for systematic reviews.

#### Dissertations

A Linear Regression Framework for Receiver Operating Characteristic (ROC) Curve Analysis Semiparametric Inferential Procedures for Comparing Multivariate ROC Curves with Interaction Terms

These dissertations are using CA-125 as an example. Not relevant to analytic validity.

#### Regulatory

510(k) SUMMARY VODAS CA 125 11 Assay

Nice analytic validity description. For FDA-approved tests, the 510(k) Summary is likely to be a good source of analytic validity information.

#### Vendors

Celerus Monoclonal Mouse Anti-CA125, Clone Ov185:1

Minimal detail on analytic validity

ARCHITECT CA 125 II: A Chemiluminescent Microparticle Assay*

Extensive detail on analytic validity

ELISA CA 125 For in vitro diagnostic use only

Describes manufacturer's analytic validity studies, recommended quality control procedures

Cancer Antigen CA125 EIA Kit Cat. # BC1013 Product User Manual

No analytic validity information

ELSA-CA 125 II - Model 18

Some information on analytic validity

CA 125 Assay Kit Search

Provides a list of seven commercial kits

#### Miscellaneous

Thai Lab Online - Tumor Markers: CA125 Nonmucinous Ovarian Carcinomas

No details on analytic validity of this commercial assay

Duke EPC - Genomic Tests for Ovarian Cancer Detection and Management

Contains a chapter on the analytic validity of CA-125 tests.

Commercializing the Next Generation of Molecular Diagnostics and Therapeutics

Presentation notes the absence of analytic validity information for EGAPP-sponsored reviews

Time-Resolved Immunofluorometric Assay for the Ovarian Carcinoma-Associated Antigenic Determinant CA 125 in Serum

Publication by Boerman et al. in Clinical Chemistry 1987;33(12): 2191-2194. Describes process of developing a modified assay with “extended shelf life and reduced analysis time with no loss of sensitivity and an extended analytic range.”

[underlined: Technical evaluation of the Beckman Coulter OV-Monitor (CA 125 antigen) immunoassay]

A published paper describing the analytic validity of a new commercial CA-125 assay by Yagmar et al. in Clinical Chemical Laboratory Medicine. Volume 44, Issue 4, Pages 420–422, ISSN (Online) 1437-4331, ISSN (Print) 1434-6621, DOI: 10.1515/CCLM.2006.083, 01/04/2006

### Quality Rating Criteria

Google search strings:

(“quality rating” OR “quality assessment” OR “methodological quality” OR “quality criteria” OR “quality measure” OR “assessment tool” OR “methodological criteria”) (“laboratory test” OR “laboratory testing” OR “genetic test” OR “genetic testing” OR biomarker)

(utility OR validity OR grading OR checklist OR scale OR rating OR instrument OR “assessment tool” OR methodological) (“laboratory test” OR “laboratory testing” OR “genetic test” OR “genetic testing” OR biomarker)

(utility OR validity OR grading OR checklist OR scale OR rating OR instrument OR “assessment tool” OR methodological) (“laboratory test” OR “laboratory testing” OR “genetic test” OR “genetic testing” OR biomarker) (diagnostic OR systematic OR quality)

“Standards for Reporting of Diagnostic Accuracy” OR STARD OR “tumor marker utility grading system” OR TMUGS OR “tumour marker prognostic studies”