# Appendixes

Appendix A Methods of Identifying the Literature

Appendix B Examples of Testing Scenarios