# Acronyms and Abbreviations

ACCE: Analytic validity; Clinical validity; Clinical utility; and Ethical, legal, and social implications
AHRQ: Agency for Healthcare Research and Quality
CDC: Centers for Disease Control and Prevention
CLEP: Clinical Laboratory Evaluation Program of New York State
CLIA: Clinical Laboratory Improvement Amendments
CMS: Centers for Medicare and Medicaid Services
EGAPP: Evaluation of Genomic Applications in Practice and Prevention initiative
EPC: Evidence-based Practice Center
NIH: National Institutes of Health
SACGHS: Secretary's Advisory Committee on Genetics, Health, and Society
USPSTF: U.S. Preventive Services Task Force