# References

1 Clarke M, Alderson P, Chalmers I. Discussion sections in reports of controlled trials published in general medical journals. JAMA. 2002;287(21):2799-801. [pmid: 12038916].
2 Clarke M, Chalmers I. Discussion sections in reports of controlled trials published in general medical journals: islands in search of continents?. JAMA. 1998;280(3):280-2. [pmid: 9676682].
3 Clarke M, Hopewell S, Chalmers I. Reports of clinical trials should begin and end with up-to-date systematic reviews of other relevant evidence: a status report. J R Soc Med. 2007;100(4):187-90. [pmid: 17404342].
4 Robinson KA, Goodman SN. A systematic examination of the citation of prior research in reports of randomized, controlled trials. Ann Intern Med. Jan. 4. 2011;154(1):50-5. [pmid: 21200038].
5 Robinson KA, Saldanha IJ, Mckoy NA. Frameworks for determining research gaps during systematic reviews. Methods Future Research Needs Report No. 2 AHRQ Publication No. 11-EHC043-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. [pmid: 21977524].
6 Robinson KA, Saldanha IJ, Mckoy NA. Development of a framework to identify research gaps from systematic reviews. J Clin Epidemiol. Dec. 2011;64(12):1325-30. [pmid: 21937195].