# Peer Reviewers

Jean-Marie Guise, Ph.D.

Oregon Health and Science University

Portland, OR

Melissa McPheeters, M.P.H., Ph.D.

Vanderbilt University

Nashville, TN

Steve Pearson, M.D., M.Sc.

Institute for Clinical and Economic Review

Boston, MA

P. Lina Santaguida, Ph.D.

McMaster University

Hamilton, ON, Canada

Claudia Witt, M.D., M.B.A.

Institute of Social Medicine, Epidemiology and Health Economics

Charite University Medical Center

Berlin, Germany