# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Christine Chang, M.D., M.P.H. We express our gratitude to the following individuals for their contributions to this project: Kay Dickersin, Ph.D., Steven N. Goodman, M.D., M.H.S., Ph.D., and Sean Tunis, M.D., M.Sc. We extend our appreciation to the team members from EPCs that evaluated the use of the framework (listed below), all of whom provided thoughtful advice and input.

## Participating EPCs

Blue Cross Blue Shield

Johns Hopkins University

McMaster University

Oregon Health and Science University

University of Alberta

University of Minnesota

Vanderbilt University