# Listing of Reviews Included in Retrospective Application of Framework

## Reports from Evidence-based Practice Centers (EPCs) Included in Retrospective Application of JHU Research Gaps Framework

1 Abou-Setta AM, Beaupre LA, Jones CA, et al. Pain Management Interventions for Hip Fracture. Comparative Effectiveness Review No. 30. 2011. May. Rockville, MD. Agency for Healthcare Research and Quality (US). AHRQ Publication No. 11-EHC022-EF. Rec #: 1.
2 Balk EM, Moorthy D, Obadan NO, et al. Diagnosis and Treatment of Obstructive Sleep Apnea in Adults. Comparative Effectiveness Review No. 32. Rockville, MD. Agency for Healthcare Research and Quality (US). 2011. Jul. AHRQ Publication No. 11-EHC052-EF. Rec #: 2.
3 Bennett WL, Wilson LM, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. Comparative Effectiveness Review No. 27. Rockville, MD. Agency for Healthcare Research and Quality (US). March. 2011. AHRQ Publication No. 11-EHC038-EF. Rec #: 3.
4 Chou R, McDonagh MS, Nakamoto E, et al. Analgesics for Osteoarthritis: An Update of the 2006 Comparative Effectiveness Review. Comparative Effectiveness Review No. 38. Rockville, MD. Agency for Healthcare Research and Quality (US). 2011. Oct. AHRQ Publication No. 11(12)-EHC076-EF. Rec #: 4.
5 Coleman CI, Baker WL, Kluger J, et al. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Diseas. Rockville, MD. Agency for Healthcare Research and Quality (US). 2009. Oct. Rec #: 5.
6 Gartlehner G, Hansen RA, Morgan LC, T, et al. Second-Generation Antidepressants in the Pharmacologic Treatment of Adult Depression: An Update of the 2007 Comparative Effectiveness Review. Comparative Effectiveness Review No. 46. Rockville, MD. Agency for Healthcare Research and Quality (US). 2011. Dec. AHRQ Publication No. 12-EHC012-EF. Rec #: 6.
7 Gaudet L, Singh K, Weeks L, et al. Terbutaline Pump for the Prevention of Preterm Birth. Comparative Effectiveness Review No. 35. Rockville, MD. Agency for Healthcare Research and Quality (US). 2011. Sep. AHRQ Publication No. 11-EHC068-EF. Rec #: 7.
8 Gaynes BN, Lux L, Lloyd S, et al. Nonpharmacologic Interventions for Treatment-Resistant Depression in Adults. Comparative Effectiveness Review No. 33. Agency for Healthcare Research and Quality (US). 2011. Sep. AHRQ Publication No. 11-EHC056-EF. Rec #: 8.
9 Guillamondegui OD, Montgomery SA, Phibbs FT, et al. Traumatic Brain Injury and Depression. Comparative Effectiveness Review No. 25. Agency for Healthcare Research and Quality (US). 2011. Apr. AHRQ Publication No. 11-EHC017-EF. Rec #: 9.
10 Maglione M, Ruelaz Maher A, Hu J, et al. Off-Label Use of Atypical Antipsychotics: An Update. Comparative Effectiveness Review No. 43. Agency for Healthcare Research and Quality (US). 2011. Sep. Rec #: 10.
11 Nelson HD, Fu R, Humphrey L, et al. Comparative Effectiveness of Medications To Reduce Risk of Primary Breast Cancer in Women. Comparative Effectiveness Review No. 17. Agency for Healthcare Research and Quality (US). 2009. Sep. Rec #: 11.
12 Nicholson WK, Wilson LM, Witkop CT, et al. Therapeutic Management, Delivery, and Postpartum Risk Assessment and Screening in Gestational Diabetes. Evidence Report/Technology Assessment No. 162. Rockville, MD. Agency for Healthcare Research and Quality (US). 2008. Mar. AHRQ Publication No. 08-E004. Rec #: 12.
13 Phung OJ, Coleman CI, Baker EL, et al. Effectiveness of Recombinant Human Growth Hormone (rhGH) in the Treatment of Patients With Cystic Fibrosis. Comparative Effectiveness Review No. 23. Agency for Healthcare Research and Quality (US). 2010. Oct. AHRQ Publication No. 11-EHC003. Rec #: 13.
14 Samson DJ, Ratko TA, Rothenberg BM, et al. Comparative Effectiveness and Safety of Radiotherapy Treatments for Head and Neck Cancer. Comparative Effectiveness Review No. 20. Agency for Healthcare Research and Quality (US). 2010. May. Rec #: 14.
15 Sanders GD, Coeytaux R, Dolor RJ, et al. Angiotensin-Converting Enzyme Inhibitors (ACEIs), Angiotensin II Receptor Antagonists (ARBs), and Direct Renin Inhibitors for Treating Essential Hypertension: An Update. Comparative Effectiveness Review No. 34. Agency for Healthcare Research and Quality (US). 2011. Jun. AHRQ Publication No. 11-EHC063-EF. Rec #: 15.
16 Seida J, Schouten J, Mousavi S, et al. Comparative Effectiveness of Nonoperative and Operative Treatment for Rotator Cuff Tears. Comparative Effectiveness Review No. 22. Agency for Healthcare Research and Quality (US). 2010. Jul. AHRQ Publication No. 10-EHC050. Rec #: 16.
17 Sharma M, Ansari MT, Soares-Weiser K, et al. Comparative Effectiveness of Lipid-Modifying Agents. Comparative Effectiveness Review No. 16. 2009. Sep. Rec #: 17.
18 Warren Z, Veenstra-VanderWeele J, Stone W, et al. Therapies for Children With Autism Spectrum Disorders. Comparative Effectiveness Review No. 26. Agency for Healthcare Research and Quality (US). 2011. Apr. AHRQ Publication No. 11-EHC029-EF. Rec #: 18.
19 Yank V, Tuohy CV, Logan AC, et al. Comparative Effectiveness of Recombinant Factor VIIa for Off-Label Indications vs. Usual Care. Comparative Effectiveness Review No. 21. Agency for Healthcare Research and Quality (US). 2010. May. Rec #: 19.

## Cochrane Reviews Included in Retrospective Application of JHU Research Gaps Framework

1 Adams E, Thomson A, Maher C, et al. Mechanical devices for pelvic organ prolapse in women. Cochrane Database Syst Rev. 2004;(2):CD004010. Rec #: 20. [pmid: 15106231].
2 Bamigboye AA, Smyth R. Interventions for varicose veins and leg oedema in pregnancy. Cochrane Database Syst Rev. 2007;(1):CD001066. Rec #: 21. [pmid: 17253454].
3 Costa J, Espirito-Santo C, Borges A, et al. Botulinum toxin type A therapy for cervical dystonia. Cochrane Database Syst Rev. 2005;(1):CD003633. Rec #: 22. [pmid: 15674910].
4 Eccleston C, Williams AC, Morley S. Psychological therapies for the management of chronic pain (excluding headache) in adults. Cochrane Database Syst Rev. 2009;(2):CD007407. Rec #: 23. [pmid: 19370688].
5 Escribano J, Balaguer A, Pagone F, et al. Pharmacological interventions for preventing complications in idiopathic hypercalciuria. Cochrane Database Syst Rev. 2009;(1):CD004754. Rec #: 24. [pmid: 19160242].
6 Ford AC, Delaney BC, Forman D, et al. Eradication therapy for peptic ulcer disease in Helicobacter pylori positive patients. Cochrane Database Syst Rev. 2006;(2):CD003840. Rec #: 25. [pmid: 16625592].
7 Foster G, Taylor SJ, Eldridge SE, et al. Self-management education programmes by lay leaders for people with chronic conditions. Cochrane Database Syst Rev. 2007;(4):CD005108. Rec #: 26. [pmid: 17943839].
8 Gagnon AJ, Sandall J. Individual or group antenatal education for childbirth or parenthood or both. Cochrane Database Syst Rev. 2007;(3):CD002869. Rec #: 27. [pmid: 17636711].
9 Hemila H, Koivula TT. Vitamin C for preventing and treating tetanus. Cochrane Database Syst Rev. 2008;(2):CD006665. Rec #: 28. [pmid: 18425960].
10 Hofmeyr GJ, Kulier R. Abdominal decompression in normal pregnancy. Cochrane Database Syst Rev. 2000;(2):CD001062. Rec #: 29. [pmid: 10796233].
11 Jones PW, Greenstone M. Carbonic anhydrase inhibitors for hypercapnic ventilatory failure in chronic obstructive pulmonary disease. Cochrane Database Syst Rev. 2001;(1):CD002881. Rec #: 30. [pmid: 11279770].
12 Kelly M, Gillies D, Todd DA, et al. Heated humidification versus heat and moisture exchangers for ventilated adults and children. Cochrane Database Syst Rev. 2010;(4):CD004711. Rec #: 31. [pmid: 20393939].
13 Kuschel CA, Harding JE. Fat supplementation of human milk for promoting growth in preterm infants. Cochrane Database Syst Rev. 2000;(2):CD000341. Rec #: 32. [pmid: 10796197].
14 McGuire H, Hawton K. Interventions for vaginismus. Cochrane Database Syst Rev. 2001;(2):CD001760. Rec #: 33. [pmid: 11406006].
15 Moore RA, Derry S, McQuay HJ. Single dose oral acemetacin for acute postoperative pain in adults. Cochrane Database Syst Rev. 2009;(3):CD007589. Rec #: 34. [pmid: 19588437].
16 Nelson R, Singer M. Primary repair for penetrating colon injuries. Cochrane Database Syst Rev. 2003;(3):CD002247. Rec #: 35. [pmid: 12917927].
17 Osiri M, Shea B, Robinson V, et al. Leflunomide for treating rheumatoid arthritis. Cochrane Database Syst Rev. 2003;(1):CD002047. Rec #: 36. [pmid: 12535423].
18 Peinemann F, Grouven U, Hemkens LG, et al. Low-dose rate brachytherapy for men with localized prostate cancer. Cochrane Database Syst Rev. 2011;(7):CD008871. Rec #: 37. [pmid: 21735436].
19 Petsky HL, Cates CJ, Li A, et al. Tailored interventions based on exhaled nitric oxide versus clinical symptoms for asthma in children and adults. Cochrane Database Syst Rev. 2009;(4):CD006340. Rec #: 38. [pmid: 19821360].
20 Piromchai P, Thanaviratananich S, Laopaiboon M. Systemic antibiotics for chronic rhinosinusitis without nasal polyps in adults. Cochrane Database Syst Rev. 2011;(5):CD008233. Rec #: 39. [pmid: 21563166].
21 Sackley C, Disler PB, Turner-Stokes L, et al. Rehabilitation interventions for foot drop in neuromuscular disease. Cochrane Database Syst Rev. 2009;(3):CD003908. Rec #: 40. [pmid: 19588347].
22 Sailas E, Fenton M. Seclusion and restraint for people with serious mental illnesses. Cochrane Database Syst Rev. 2000;(2):CD001163. Rec #: 41. [pmid: 10796606].
23 Swadpanich U, Lumbiganon P, Prasertcharoensook W, et al. Antenatal lower genital tract infection screening and treatment programs for preventing preterm delivery. Cochrane Database Syst Rev. 2008;(2):CD006178. Rec #: 42. [pmid: 18425940].
24 Uman LS, Chambers CT, McGrath PJ, et al. Psychological interventions for needle-related procedural pain and distress in children and adolescents. Cochrane Database Syst Rev. 2006;(4):CD005179. Rec #: 43. [pmid: 17054243].
25 van der Schans C, Prasad A, Main E. Chest physiotherapy compared to no chest physiotherapy for cystic fibrosis. Cochrane Database Syst Rev. 2000;(2):CD001401. Rec #: 44. [pmid: 10796781].
26 van Duijvenbode IC, Jellema P, van Poppel MN, et al. Lumbar supports for prevention and treatment of low back pain. Cochrane Database Syst Rev. 2008;(2):CD001823. Rec #: 45. [pmid: 18425875].
27 Vemgal P, Ohlsson A. Interventions for non-oliguric hyperkalaemia in preterm neonates. Cochrane Database Syst Rev. 2007;(1):CD005257. Rec #: 46. [pmid: 17253550].
28 Villar HC, Saconato H, Valente O, et al. Thyroid hormone replacement for subclinical hypothyroidism. Cochrane Database Syst Rev. 2007;(3):CD003419. Rec #: 47. [pmid: 17636722].
29 Wang Y, Pan T, Wang Q, et al. Additional bedtime H2-receptor antagonist for the control of nocturnal gastric acid breakthrough. Cochrane Database Syst Rev. 2009;(4):CD004275. Rec #: 48. [pmid: 19821323].
30 Yorke J, Fleming SL, Shuldham CM. Psychological interventions for adults with asthma. Cochrane Database Syst Rev. 2006;(1):CD002982. Rec #: 49. [pmid: 16437449].
31 Youssef M A, Al-Inany HG, Evers JL, et al. Intra-venous fluids for the prevention of severe ovarian hyperstimulation syndrome. Cochrane Database Syst Rev. 2011;(2):CD001302. Rec #: 50. [pmid: 21328249].