# Results

## Number Needed to Treat and Number Needed to Harm

Tables 3A and 3B show the NNT and NNH associated with use of low-dose aspirin in men and women respectively. Both the NNT and NNH for aspirin consistently declined with increasing age because of the increase in baseline incidence rates for all outcomes across age categories. Apart from the effect of aspirin on outcomes (which we assume is constant on the relative scale here), the increasing baseline incidence rate across increasing age categories affected estimates of NNT and NNH. Among men in the oldest age category, a 35 percent relative increase in the risk of hemorrhagic stroke with aspirin (Appendix Table A-1) still resulted in a low absolute risk of such events (NNH 1,786) because of the low baseline incidence rate of hemorrhagic stroke.

Table 3A Number needed to treat and number needed to harm in person-years for primary prevention with low-dose aspirin in men for four age categories

Age category in years | 45–54 | 55–64 | 65–74 | 75–84
Benefit outcomes NNT (95% CI)
MI | 1,786 [962 - NA] | 1,153 [621 - NA] | 769 [414 - NA] | 511 [275 - NA]
Major ischemic * stroke | 6,411 [NNT 3,087 - NNH 41,667] | 3,077 [NNT 1,482 - NNH 20,000] | 1,374 [NNT 662 - NNH 8,929] | 713 [NNT 343 - NNH 4,630]
Harm outcomes NNH (95% CI)
Major hemorrhagic stroke | 14,286 [6,173 – 500,001] | 7,143 [3087 – 250,001] | 3,572 [1,544 – 125,001 | 1,786 [772 – 62,501]
Major GI bleeds | 1,344 [833 – 2,688] | 645 [400 – 1,290] | 329 [204 – 658] | 202 [125 – 403]

CI = confidence interval; GI = gastrointestinal; MI = myocardial infarction; NA = not applicable because CIs for RR approximate 1; NNH = number needed to harm; NNT = number needed to treat; RR = relative risk

* The 95% CIs for ischemic stroke (RR 0.87; 95% CI, 073 –1.02) include the possibilities of both benefit and harm and thus we report NNT as well as NNH respectively. The NNT is lower because it reflects the lower limit of the CI, and the NNH is higher because it reflects the upper limit of the CI.

Table 3B Number needed to treat and number needed to harm in person-years for primary prevention with low-dose aspirin in women for four age categories

Age Category in years | 45–54 | 55–64 | 65–74 | 75–84
Benefit outcomes NNT (95% CI)
MI | 5,953 [3,206 - NA] | 2381 [1,283 - NA] | 1,520 [819 - NA] | 872 [470 - NA]
Major ischemic stroke^*^ | 8,548 [NNT 4,116 - NNH 55,556] | 3487 [NNT 1852 - NNH 25,000] | 2,137 [NNT 1,029 - NNH 13,889] | 1,026 [NNT 494 - NNH 6,667]
Harm outcomes NNH [ 95% CI]
Major hemorrhagic stroke | 28,572 [12,346 – 1,000,001] | 9,524 [4,116 – 333,334] | 5,715 [2,470 – 200,000] | 2,598 [1,123 – 90,910]
Major GI bleeds | 2,688 [1,667 – 5,376] | 1,344 [833 – 2,688] | 701 [435 – 1,403] | 436 [270 – 872]

* The 95% CIs for ischemic stroke (RR 0.87; 95% CI, 073–1.02) include the possibilities of both benefit and harm and thus we reported NNT as well as NNH respectively. The NNT is lower because it reflects the lower limit of the CI, and the NNH is higher because it reflects the upper limit of the CI.

CI = confidence interval; GI = gastrointestinal; MI = myocardial infarction; NA = not applicable because CIs for RR approximate 1; NNH = number needed to harm; NNT = number needed to treat; RR = relative risk

Among women age 45–54 years, a 62 percent relative increase in the risk of major gastrointestinal (GI) bleeds with aspirin (Appendix A) resulted in an NNH of 2,688. The NNH for major GI bleeds for other age and sex specific categories were even smaller because of the relatively higher baseline incidence rates of GI bleeds across these categories.

Since the estimates of some of the rare harmful effects, such as hemorrhagic stroke, were imprecise, we had more uncertainty around the NNT and NNH estimates. The 95% confidence interval (CI) for ischemic stroke included the possibilities of both benefit and harm (relative risk [RR] 0.87; 95% confidence interval [CI], 0.73–1.02) and thus we reported the NNT as well as the NNH, respectively. This illustrates the challenge of conveying sampling uncertainty to end users of the analysis.

### Sensitivity Analysis for the Number Needed to Treat and Number Needed to Harm Approach Using Baseline Incidence Rates from the Trials

Below we present the results of the sensitivity analysis for the NNT and NNH approach using baseline incident rates from the trials. Since the baseline incidence rates in the trials were lower than that of the observational studies (Appendix Table A-4), the respective NNTs and NNHs in this sensitivity analysis were higher for all four outcomes for both men and women (Tables 4A and 4B).

Table 4A Sensitivity analysis for number needed to treat and number needed to harm in person-years for primary prevention with low-dose aspirin in men

Outcomes | NNT(95% CI)
MI | 1,299 [700 - NA]
Major ischemic stroke^*^ | 3,664 [NNT 1,764 - NNH 23,810]
| NNH(95% CI)
Major hemorrhagic stroke | 9,524 [4,116 – 333,334]
Major GI bleeds | 1,793 [1,112 – 3,585]

* The 95% CIs for ischemic stroke (RR 0.87; 95% CI, 073–1.02) include the possibilities of both benefit and harm and thus we reported NNT as well as NNH respectively. The NNT is lower because it reflects the lower limit of the CI, and the NNH is higher because it reflects the upper limit of the CI.

NA= Not applicable because CIs for RR approximate 1.

NNT = Number needed to treat, NNH = Number needed to harm, CI = confidence interval, MI = Myocardial infarction, GI = Gastrointestinal, RR = Relative risk

Table 4B Sensitivity analysis for number needed to treat and number needed to harm in person-years for primary prevention with low-dose aspirin in women

Outcomes | NNT (95% CI)
MI | 7,143 [3,847 - NA]
Major ischemic stroke^*^ | 6,994 [NNT 3,368 - NNH 45,455]
| NNH (95% CI)
Major hemorrhagic stroke | 14,286 [6,173 – 500,000]
Major GI bleeds | 3,226 [2,000 – 6,452]

* The 95% CIs for ischemic stroke (RR 0.87; 95% CI, 073–1.02) include the possibilities of both benefit and harm and thus we report NNT as well as NNH respectively. The NNT is lower because it reflects the lower limit of the CI, and the NNH is higher because it reflects the upper limit of the CI.

NA= Not applicable because CIs for RR approximate 1.

NNT = Number needed to treat, NNH = Number needed to harm, CI = confidence interval, MI = Myocardial infarction, GI = Gastrointestinal, RR = Relative risk

Our estimates for the NNT and NNH in person-years differ from those reported by Berger et al. for the outcomes of major adverse cardiovascular events and bleeds in the trials.9 They reported a NNT of 253 (95% CI, 163–568) to prevent one major cardiovascular event and NNH of 261 (95% CI, 182–476) to cause one major bleed with aspirin over the mean duration of the trials (6.9 years). An important difference is that they used cumulative incidences as the metric for baseline risks (i.e., number of persons with an event during the entire followup period divided by the total number of persons) and did not use incidence rates (number of events per person-time) as we did. Thus, their results are not directly comparable to ours. Also, they used the baseline risk entirely from RCT data (as we did in a sensitivity analysis), which excluded participants with a history of GI events. Finally, they implicitly assumed cardiovascular events and major bleeds were of equal weight, stating that for 1,000 people treated with aspirin over 5 years three cardiovascular events would be prevented and three major bleeds would be induced, compared with no aspirin use. We chose to report separate NNTs for different outcomes, as we considered them to be too dissimilar in terms of their importance to participants.

## Gail/National Cancer Institute Approach

Tables 5 and 6 show the absolute numbers of expected events over 10 years without or with low-dose aspirin for 1,000 men or women, respectively. Take, for example, men age 55 to 64 years. The expected number of MIs per 1,000 untreated men over 10 years was 57. This was a little less than what would be calculated by simply multiplying the incidence rate of 6.2 MIs per 1,000 person-years by 10 years (see Table 1) because we considered death as a competing risk that prevents MIs from occurring in those who die early. As age increased, the impact of death became larger. For example, the expected number of GI bleeds in untreated men age 75 to 84 years was 56 over 10 years with death as a competing risk. This is considerably lower than the 480 that would be expected without considering death as a competing risk (Table 1).

Table 5 Expected number of events without and with low-dose aspirin in men *

Outcomes | Number of Expected Events Over 10 Years Per 1,000 Men
| Without aspirin | | | | With aspirin
Age categories in years | 45–54 | 55–64 | 65–74 | 75–84 | 45–54 | 55–64 | 65–74 | 75–84
MI | 38 | 57 | 79 | 96 | 33 | 49 | 68 | 83
Major ischemic stroke | 14 | 27 | 55 | 84 | 12 | 24 | 48 | 74
Major hemorrhagic stroke | 2 | 4 | 8 | 12 | 3 | 5 | 11 | 17
Major GI bleeds | 12 | 24 | 42 | 56 | 19 | 38 | 67 | 89

GI = gastrointestinal; MI = myocardial infarction; RR = relative risk

* We considered all-cause mortality a competing risk that was equal for both groups (i.e. RR of 1.0).

Table 6 Expected events without and with low-dose aspirin in women *

Outcomes | Number of expected events over 10 years per 1,000 women
| Without aspirin | | | | With aspirin
Age categories in years | 45–54 | 55–64 | 65–74 | 75–84 | 45–54 | 55–64 | 65–74 | 75–84
MI | 12 | 29 | 42 | 63 | 10 | 25 | 37 | 54
Major ischemic stroke | 10 | 22 | 38 | 66 | 9 | 20 | 33 | 58
Major hemorrhagic stroke | 1 | 3 | 6 | 9 | 1 | 4 | 7 | 13
Major GI bleeds | 6 | 12 | 21 | 29 | 10 | 19 | 34 | 46

* All-cause mortality is considered as a competing risk and equal for both groups (i.e. relative risk of 1.0).

MI = Myocardial infarction, GI = Gastrointestinal

Tables 5 and 6 also allow for a comparison between the numbers of expected events without and with aspirin in men and women, respectively. For example, the difference in the number of MIs for men age 65 to 74 years was 11 (79 minus 68) over 10 years. This means that 11 MIs were prevented by aspirin, based on a RR reduction of 14 percent from the meta-analysis by Berger et al.9 Aspirin reduced major ischemic strokes to a similar extent (13 percent RR reduction). At the same time, aspirin increased the number of major hemorrhagic strokes (35 percent RR increase, e.g., excess of three hemorrhagic strokes for men age 65 to 74 years) and the number of major GI bleeds (62 percent RR increase, e.g., excess of 25 major GI bleeds for men age 65 to 74 years) over 10 years.

Table 7 shows the Gail/NCI index for men and women for the main analysis and all three sensitivity analyses. When we used relative weights as reported in the literature13 (e.g., major stroke was weighted about twice as much as MI and about 8 times as much as GI bleeds), aspirin caused slightly more beneft than harm in all age categories of men and women (i.e. positive Gail/NCI index). When we weighted the outcomes equally (sensitivity analysis I), the harm from aspirin was greater than the benefit (i.e., negative Gail/NCI index). In sensitivity analysis II, where we weighted strokes as very important with a weight of 1, MIs as important with a weight of 0.5, and GI bleeds as unimportant with a weight of 0, aspirin provided net benefit for all sex and age categories.

Table 7 Gail/NCI index to estimate the relative weighted number of harm minus benefit outcomes

| Gail/NCI benefit harm comparison index per 1,000 persons treated over 10 years for four age categories^*^
| Men | | | | Women
Age (years) | 45–54 | 55–64 | 65–74 | 75–84 | 45–54 | 55–64 | 65–74 | 75–84
Main analysis using empirically derived relative weights | 2^*^ | 3 | 3 | 5 | 1 | 2 | 3 | 5
Sensitivity analysis I, equal preference of outcomes | −1^†^ | −5 | −10 | −14 | −1 | −1 | −4 | −4
Sensitivity analysis II, only very important and important outcomes^‡^ | 4^§^ | 6 | 9 | 13 | 2 | 4 | 6 | 9
Sensitivity analysis III, based on control group event rates from aspirin RCTs | 4^**^ | | | | 1

* Negative values of index= aspirin harmful (harm events [hemorrhagic stroke and severe GI bleeds] outweigh benefit events [myocardial infarctions and severe ischemic stroke])

† The values for the index are higher in sensitivity analysis I than in the main analysis and sensitivity analyses II and III because severe GI bleeds have more weight in sensitivity analysis I (i.e. relative weight of 1.0) compared to the other analysis (0.2 in the main analysis and sensitivity analysis III, and 0 in sensitivity analysis II).

‡ Weight of 1 for very important outcomes such as severe stroke, 0.5 for important outcomes such as myocardial infarction and 0 for gastrointestinal bleeds

§ Positive values of index = aspirin beneficial (prevented benefits outweigh harm events)

** Mean age across RCTs 53 to 65 years for men and 55 to 65 years for women. Since no age-specific incidence rates were available (Table 1), benefit and harm comparison estimates are not available for the four age categories.

Finally, when we based the analyses on baseline incidence rates of the placebo groups in the trials (sensitivity analysis III), aspirin use was associated with more benefit than harm. For sensitivity analysis III, we did not make age-specific benefit and harm comparisons because trials only reported baseline incidence rates for the entire male or female trial populations. Baseline incidence rates in the trials were comparable to those from surveillance data, with the important exception of GI bleeds (see next paragraph). The baseline incidence rate of MI in the trials was 5.6 per 1,000 person-years for men and 1.0 per 1,000 person-years for women. Compared with the baseline incidence rates in Table 1, the trial-based incidence rates compared well with those observed in the same age categories (45 to 54 and 55 to 64 years). We observed similar age-specific baseline incidence rates for major ischemic strokes (2.1 per 1,000 person-years for men and 1.1 per 1,000 person-years for women), major hemorrhagic strokes (0.3 per 1,000 person-years for men and 0.2 per 1,000 person-years for women), and for death (7.9 per 1,000 person-years for men and 3.5 per 1,000 person-years for women). Thus, the difference in the expected number of MIs, major strokes, and deaths for 1,000 men and women with or without aspirin treatment was similar, regardless of whether we based baseline incidence rates on surveillance data or trial data.

The baseline incidence rates for GI bleeds differed when comparing trial data with population-based surveillance data. In the trials, the baseline incidence of GI bleeds was lower (1 per 1,000 person-years for men and 0.5 per 1,000 person-years for women) than in the population-based surveillance data (by a factor of about 2). As a consequence, using the baseline incidence rates of GI bleeds from trials, the number of GI bleeds caused by aspirin was lower than found in population-based surveillance data; and, as a result, the benefit and harm comparison estimates were positive and thus favored aspirin.

## Comparison of Approaches

Table 8 summarizes the characteristics of the NNT and NNH approach and the Gail/NCI approach and allows for a comparison between the two approaches. We show examples where we used baseline incidence rates for men aged 45–54 years (example 1) and men aged 75–84 years (example 2). The NNT approach estimates the NNT directly using equation 6 (see Table 8). The Gail/NCI approach first estimates the number of expected events while considering mortality (or any other outcome) as a competing risk (equations 1 and 2 above and in Table 8), and then takes the difference in events between treated and untreated subjects (equation 3). One can easily transform the NNT based on incidence rates to express the number of events per person-time or per a certain number of persons treated over a specific time periods, respectively (equation 7), and thereby facilitate comparison with estimates from the Gail/NCI approach. Thus, although the target estimates researchers commonly use differ markedly between the NNT and NNH approach and the Gail/NCI approach, equation 7 for the NNT and NNH approach (Table 8) shows that we can easily make the results comparable. The numerical comparison of the NNT and NNH approach with the Gail/NCI approach is restricted to a single outcome since NNT only deals with one outcome at a time whereas the Gail/NCI approach provides an index to summarize the effects of treatment across all outcomes. Thus, the numerical examples presented in Table 8 do not compare the NNT and NNH approach with the full Gail/NCI approach.

Table 8 Comparison of the number needed to treat and number needed to harm approach and the Gail/National Cancer Institute approach^*^

Characteristics to be Compared | Number Needed to Treat and Number Needed to Harm (Unit= Person Years) | Gail/National Cancer Institute
Model: mathematical equations | Based on constant incidence rate model Equation 5: (NNT general formula); NNT = 1/Absolute Risk Reduction 5 | Based on constant hazard rate exponential model Equation 1: (Number of expected events per 1,000 subjects without aspirin over 10 years); Nx,p = 1,000*{Ix/(Ix+ M)}*[1−exp{−10(Ix+ M)}] 1; Please note that the numbering of equations in this table is consistent with the numbering of equations in the text
Model: mathematical equations | Equation 6: NNT formula for incidence rate (number of person-years of treatment needed to prevent one event); NNT = 1/[Ix − Ix*RRx)] 6 | Equation 2: (Number of expected events per 1,000 subjects with aspirin over 10 years); Nx,t = 1,000*{RRx*Ix/(RRx*Ix+ M)}*[1−exp{− 10(RRx*Ix+ M)}] 2
Model: mathematical equations | Equation 7: Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years; Difference Nx = 1,000/{1/[10*Ix − 10*Ix*RRx)]} 7 | Equation 3: (Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years); Difference Nx =Nx,p − Nx,t 3
Model: mathematical equations | Ix = Baseline incidence rate for a specific outcome (x) RRx = RR of aspirin for a specific outcome (x) Nx = Difference in the number of events (N) for a specific outcome (x) per 1,000 subjects without and with aspirin over 10 years) | Equation 4: (Sum of differences in events per 1,000 subjects without and with aspirin over 10 years); Index(W1, W2, W3)=W1 ∑ Nx_1_ + W2 ∑ Nx_2_ + W3 ∑ Nx_3_ 4; Nx, p = number of events (N) for a specific outcome (x) per 1,000 subjects over 10 years in subjects without aspirin (p) Ix = Baseline incidence rate for a specific outcome (x), approximates hazard rates M = all-cause mortality Nx, t = number of events (N) for a specific outcome (x) per 1,000 subjects over 10 years in subjects with aspirin (t) RRx = RR of aspirin for a specific outcome (x), approximates hazard ratio Nx = Difference in the number of events (N) for a specific outcome (x) per 1,000 subjects without and with aspirin over 10 years)
Example 1 | Low baseline incidence rate for MI in men age 45–54 years and low competing mortality risk MI: Ix = 0.004 per person-year; RRx aspirin vs. placebo: = 0.86; All-cause mortality: M = 0.005 per person-year
| Equation 7: (Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years) | Equation 3: (Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years while considering death as competing risk)
| Difference Nx = 1,000/{1/(10*Ix − 10*Ix*RRx)} = 1,000/178.6 = 6 events (5.6 with one decimal) | Difference Nx =Nx,p −Nx,t = 38−33 = 5 events (5.3 with one decimal)
Example 2 | Low baseline incidence rate for MI in men age 75–84 years and moderate competing mortality risk MI: Ix = 0.014 per person-year; RRx aspirin vs. placebo: = 0.86; All-cause mortality: M = 0.067 per person-year
| Equation 7: (Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years) | Equation 3: (Difference in the number of expected events per 1,000 subjects without and with aspirin over 10 years while considering death as competing risk)
| Difference Nx = 1,000/{1/(10*Ix − 10*Ix*RRx)} = 1,000/51.0 = 20 (19.6 with one decimal) | Difference Nx =Nx,p −Nx,t = 96−83 = 13 events (12.7 with one decimal)
Target estimate (target of inference) | The NNT is the number of person-years of treatment with aspirin, rather than with comparator, for one patient to be protected from MI or ischemic stroke. The NNH is the number of person-years of treatment with aspirin, rather than with placebo or comparators, for one additional patient to be harmed by an adverse bleeds event | Sum of differences in the (weighted) number of harm (GI bleeds or hemorrhagic stroke) and benefit (MI and ischemic stroke) outcomes for aspirin compared with placebo per 1,000 men/women over 10 years
Input parameters: Baseline incidence rate for benefit and harm outcomes | Baseline incidence rates (per 1,000 person-years) without aspirin based on surveillance data in Table 1 in report | Baseline incidence rates (per 1,000 person-years) without aspirin based on surveillance data in Table 1 in report
Input parameters: Treatment effect | MI: RRx = 0.86 [0.74,1.00] Ischemic stroke: RRx = 0.87 [0.73,1.02] Hemorrhagic stroke: RRx =1.35 [1.01,1.81] GI bleed: RRx= 1.62 [1.31,2.00] | MI: RRx = 0.86 [0.74,1.00] Ischemic stroke: RRx = 0.87 [0.73,1.02] Hemorrhagic stroke: RRx =1.35 [1.01,1.81] GI bleed: RRx= 1.62 [1.31,2.00]
Input parameters: Relative Weights/utilities | NA | MI: Relative weight = 0.45 Ischemic stroke: Relative weight= 0.89 Hemorrhagic stroke: Relative weight= 0.89 GI bleed: Relative weight=0.20
Input parameters: Competing risks | NNT and NNH is unable to account for competing risk | Competing risk of mortality based on population-based mortality rates stratified for age and gender.
Input parameter: Time | Person-years of exposure | Estimated for 10 years
Assumptions: baseline risk over time | Incidence rate of all outcomes without treatment did not change over time. | Incidence rate of all outcomes without treatment did not change over time.
Assumptions: Treatment effect over time | Aspirin associated RR reductions or RR increases for benefit and harm outcomes did not change over time. | Aspirin associated RR reductions or RR increases for benefit and harm outcomes did not change over time. RR assumed to approximate hazard ratio.
Assumptions: weight/utilities | NNT and NNH allow end users to put respective relative weights on outcomes. | Relative weights for outcomes came from a small sample of participants considering aspirin for primary prevention13
Assumptions: competing risks | NNT and NNH cannot account for competing risk. | Competing risks are assumed to reflect the risk of an untreated population.
Assumptions: Applicability | RR reductions in benefits or RR increase in harms from the trials were applicable to the source populations from which estimates of the baseline risks originated. | RR reductions in benefits or RR increase in harms from the trials were applicable to the source populations from which estimates of the baseline risks originated.
Assumptions: Risk profiles | This approach considered different risk profiles of the population, based on characteristics including age and sex. It did not consider additional characteristics such as race, blood pressure, or cholesterol levels because not all outcome incidence rates were available. | This approach considered different risk profiles of the population, based on characteristics including age and sex. It did not consider additional characteristics such as race, blood pressure, or cholesterol levels because not all outcome incidence rates were available.

CI = confidence interval; GI = gastrointestinal; MI = myocardial infarction; NA = not applicable; NNH = number needed to harm; NNT = number needed to treat; RR = relative risk

* The numbering of equations in this table is consistent with the numbering of equations in the text.

Looking at example 1, where both the baseline incidence for MI and the risk for mortality is low (among men age 45–54 years), the number of MIs prevented per 1,000 men treated with aspirin over 10 years, compared with no aspirin, is 5.6 according to the NNT approach and 5.3 according to the Gail/NCI approach. The impact of the competing risks is small (difference of 5.6 and 5.3, respectively). Therefore, the NNT and NNH approach, which does not consider competing risks, provides a good approximation of the number of events prevented or in excess for treated versus untreated subjects. In contrast, example 2 illustrates the effect of a larger competing risk, in the setting of a still relatively low baseline incidence rate for MIs. In men age 75–84 years, the difference between the NNT approach and Gail/NCI approach is 6.9 (19.6 minus 12.7) prevented MIs per 1,000 men treated with aspirin over 10 years compared with no aspirin.

As mentioned above, the NNT and NNH approach provides separate estimates for each outcome. In contrast, the Gail/NCI index provides an index that summarizes the (weighted) number of events prevented or in excess by treatment across outcomes (equation 4 in Table 8) per a certain number of persons treated over a specific time horizon. Some of the input parameters needed (e.g., treatment effect and baseline risk estimates) are the same for both approaches. However, only the Gail/NCI approach considers relative weights reflecting the importance of the different outcomes. The assumptions underlying both approaches are similar; we noted the differences in Table 8.