# References

1 Boyd CM, Singh S, Varadhan R, et al. Methods for Benefit and Harm Assessment in Systematic Reviews Reviews. Methods Research Report. (Prepared by Johns Hopkins University Evidence-based Practice Center under contract No. 290-2007-10061-I). AHRQ Publication No. 12(13)-EHC150-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2012.
2 Bennett WL, Wilson LM, Bolen S, et al. Oral Diabetes Medications for Adults With Type 2 Diabetes: An Update. AHRQ Publication No. 11-EHC038-EF. Rockville, MD. Agency for Healthcare Research and Quality. March. 2011.
3 Matchar DB, McCrory DC, Orlando LA, et al. Comparative Effectiveness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension. AHRQ Publication No. 08-EHC003-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2007.
4 Bravata DM, McDonald KM, Gienger AL, et al. Comparative Effectiveness of Percutaneous Coronary Interventions and Coronary Artery Bypass Grafting for Coronary Artery Disease. AHRQ Publication No. 08-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2007.
5 Coleman CI, Baker WL, Kluger J, et al. Comparative Effectiveness of Angiotensin Converting Enzyme Inhibitors or Angiotensin II Receptor Blockers Added to Standard Medical Therapy for Treating Stable Ischemic Heart Disease. AHRQ Publication No. 10-EHC002-EF. Rockville, MD. Agency for Healthcare Research and Quality. October. 2009.
6 Bolen S, Wilson L, Vassy J, et al. Comparative Effectiveness and Safety of Oral Diabetes Medications for Adults With Type 2 Diabetes. AHRQ Publication No. 07-EHC010-EF. Rockville, MD. Agency for Healthcare Research and Quality. July. 2007.
7 Bennett WL, Maruthur NM, Singh S, et al. Comparative effectiveness and safety of medications for type 2 diabetes: an update including new drugs and 2-drug combinations. Ann Intern Med. 2011;154(9):602-13. [pmid: 21403054].
8 Chong J, Poole P, Leung B, et al. Phosphodiesterase 4 inhibitors for chronic obstructive pulmonary disease. Cochrane Database Syst Rev. May. 11. 2011;(5):CD002309. [pmid: 21563134].
9 Berger JS, Lala A, Krantz MJ, et al. Aspirin for the prevention of cardiovascular events in patients without clinical cardiovascular disease: a meta-analysis of randomized trials. Am Heart J. 2011;162(1):115-24.E2. [pmid: 21742097].
10 Gail MH, Costantino JP, Bryant J, et al. Weighing the risks and benefits of tamoxifen treatment for preventing breast cancer. J Natl Cancer Inst. Nov. 3. 1999;91(21):1829-46. [pmid: 10547390].
11 Varadhan R, Weiss CO, Segal JB, et al. Evaluating health outcomes in the presence of competing risks: a review of statistical methods and clinical applications. Med Care. Jun. 2010;48(6 Suppl):S96-105. [pmid: 20473207].
12 National Institutes of Health: National Heart, Lung, and Blood Institute. Incidence and Prevalence: 2006 Chart Book on Cardiovascular and Lung Diseases. http://www.nhlbi.nih.gov/resources/docs/06a_ip_chtbk.pdf. Accessed October 22, 2012.
13 Man-Son-Hing M, Laupacis A, O’Connor AM, et al. Patient preference-based treatment thresholds and recommendations: a comparison of decision-analytic modeling with the probability-tradeoff technique. Med Decis Making. Oct–Dec. 2000;20(4):394-403. [pmid: 11059472].
14 Berger JS, Roncaglioni MC, Avanzini F, et al. Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. JAMA. Jan. 18. 2006;295(3):306-13. [pmid: 16418466].
15 Hernandez-Diaz S, Garcia Rodriguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Medicine. 2006;4(22).
16 Xu J, Kochanek KD, Murphy SL, et al. Deaths: final data for 2007. National Vital Statistics Reports. 2010;58(19).
17 Cates CJ. Simpson’s paradox and calculation of NNT from meta-analysis. BMC Med Res Methodol. 2002;2:1. [pmid: 11860604].
18 Cates CJ. Dr Chris Cates’ EBM Web site. http://www.nntonline.net. Accessed 14 October 2013.
19 McQuay HJ, Moore RA. Using numerical results from systematic reviews in clinical practice. Ann Intern Med. 1997;126(9):712. [pmid: 9139558].
20 Altman DG. Confidence intervals for the number needed to treat. BMJ. 1998;317:1309. [pmid: 9804726].
21 U.S. Preventive Services Task Force. Aspirin for the prevention of cardiovascular disease: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. Mar. 17. 2009;150(6):396-404. [pmid: 19293072].
22 Eichler K, Puhan MA, Steurer J, et al. Prediction of first coronary events with the Framingham Score: a systematic review. Am Heart J. May. 2007;153(5):722-31. 731.E1. 8. [pmid: 17452145].
23 Guyatt GH, Oxman AD, Vist GE, et al. GRADE: an emerging consensus on rating quality of evidence and strength of recommendations. BMJ. 2008;336(7650):924-6. [pmid: 18436948].
24 Altman DG, Andersen PK. Calculating the number needed to treat for trials where the outcome is time to an event. BMJ. 1999;319(7223):1492-5. [pmid: 10582940].
25 Shamliyan T, Kane RL, Ansari MT, et al. Development of the Quality Criteria To Evaluate Nontherapeutic Studies of Incidence, Prevalence, or Risk Factors of Chronic Diseases: Pilot Study of New Checklists. Methods Research Report. AHRQ Publication No. 11-EHC008-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2011. http://effectivehealthcare.ahrq.gov/.
26 MacLean S, Mulla S, Akl EA, et al. Patient values and preferences in decision making for antithrombotic therapy: a systematic review: antithrombotic therapy and prevention of thrombosis, 9th ed.: American College of Chest Physicians Evidence-Based Clinical Practice Guidelines. Chest. Feb. 2012;141(2 Suppl):e1S-23S. [pmid: 22315262].
27 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods for Effective Health Care. AHRQ Publication No. 10-EHC070-EF. Rockville (MD). Agency for Healthcare Research and Quality. September. 2010.