# Methods

To select the clinical question to illustrate the approaches to benefit and harm assessment, we reviewed systematic reviews from the www.effectivehealthcare.org Web site and investigators’ reference libraries.2–9 These systematic reviews addressed a wide variety of clinical questions. We selected the systematic review of the benefits and harms of low-dose aspirin for primary prevention of cardiovascular events. We chose this complex decisionmaking scenario because it needs to balance the multiple outcomes for benefit (prevention of myocardial infarction [MI], ischemic stroke) and harm (excess of gastrointestinal [GI] bleeds and hemorrhagic stroke).9 Such a complex scenario allowed us to explore how variations in baseline risk across these outcomes (risk of an outcome over a particular time period without treatment, i.e., without aspirin) and variations in their relative importance and relevance to patients (i.e., preferences) may affect the comparison of benefits and harms of aspirin. We also considered it a pragmatic choice because data were available for both benefit and harm outcomes from meta-analyses.

Although one can potentially apply several quantitative approaches to a key question, we illustrated two quantitative approaches for the assessment of benefits and harms of aspirin for primary prevention of cardiovascular events: NNT and NNH approach, and the Gail/National Cancer Institute (NCI) approach. We outlined the selection process for choosing a particular quantitative approach in a previous report.1 We based this decision on the number of outcomes available and the need for a benefit and harm comparison metric. We also wanted to compare a more commonly-used method which does not provide a benefit and harm comparison metric with another advanced method that provides a benefit and harm comparison metric to understand the assumptions, similarities, and differences in methods. Also, we selected the NNT and NNH approach because these are frequently-used metrics to judge the balance of benefits and harms, and therefore may often be available to decisionmakers. Systematic reviews conducted by the Cochrane Collaboration routinely report NNT and NNH separately. The NNT and NNH approach provides a natural point of reference for more complex approaches. We selected the Gail/NCI approach because it can consider multiple outcomes, it offers a benefit and harm comparison metric,^*^ it can consider competing risks, and it can take into account relative weights for various outcomes.10

* A benefit and harm comparison metric provides explicit quantitative information on the benefit and harm outcomes, such as by putting benefit and harm on the same scale (e.g., quality-adjusted life-years (QALYs), probability scale, risk scale, NNT/NNH ratio, etc.), resulting in a benefit and harm comparison estimate.1

## Specification of the Decisionmaking Context

We specified the decisionmaking context as the perspective of a hypothetical guideline-maker assessing the benefits and harms of aspirin in the primary prevention of cardiovascular events. We defined the target population as age 50 to 84 years, living in the United States without evidence of cardiovascular disease or stroke. We assessed the use of low dose (75–100 mg) aspirin compared with placebo using a time horizon of 10 years. The outcomes of interest were defined in terms of potential benefits of treatment in preventing MI and ischemic stroke, and potential harms of aspirin treatment including excess hemorrhagic stroke and major GI bleeds. We defined the unit of NNT as the number of person-years of exposure to treatment needed to prevent one event. We considered death from any cause as a competing risk for the Gail/NCI approach,11 which accounted for the fact that people who die (from any cause) cannot experience any of the events of interest (MI, stroke, or GI bleed) later on.

## Selection of Data Sources

The data inputs needed for a quantitative approach to benefit and harm assessment included:

a. The estimated effects of aspirin on the outcomes of MI, ischemic stroke, hemorrhagic stroke, and GI bleed;
b. The baseline risk of these outcomes without aspirin for a time horizon of 10 years; and
c. The relative weights for these outcomes. (Certain quantitative approaches for benefit and harm assessment, such as the NNT and the NNH, do not require an explicit weight for these outcomes and rely on decisionmakers to weigh the outcomes.)

There is general scientific consensus that high-quality randomized controlled trials (RCTs) and meta-analyses provide a reliable source of evidence on treatment effects of interventions, including benefits and harms. However, sometimes data on harm may not be available from RCTs, and researchers will need to retrieve data from additional sources including observational studies. Retrieving and selecting the appropriate estimates for the probabilities of benefits and harms without treatment may require additional data sources beyond RCTs. This may be particularly true when the target population is dissimilar from the trial population with respect to characteristics that influence baseline risks (e.g., age or comorbidities). An important reason to go beyond RCTs and to look to observational studies is that baseline risks, as observed in RCTs, are often not applicable to the target population of a benefit and harm assessment because of restrictive eligibility criteria. Additional data sources may include large observational studies or national surveillance data. Occasionally, when the trial populations reflect the baseline risk (for both benefit and harm outcomes) of the target population of intended users, RCTs can provide a useful source of information on baseline risk without treatment. Researchers often call any measure of the occurrence of an outcome “risk” even when they have calculated a rate. In this report we also use the term baseline risk. For all calculations in this report we refer to the actual metric used, which were primarily incidence rates (number of events per person-time) rather than cumulative incidence (i.e., the cumulative number of participants with an event over a particular period of time divided by all participants that the study observed).

We followed a transparent selection process. We prespecified that the benefit and harm estimates should be applicable to the population of interest. We relied on a previously conducted meta-analysis of RCTs for the effect estimates of aspirin on the outcomes of MI, ischemic stroke, hemorrhagic stroke, and GI bleeds.9 Additionally, we searched for data sources that described the incidence rates of cardiovascular events and GI bleeds among the target population in cohort studies.12 We expected that incidence rates may be different in the RCTs of the meta-analysis as compared with those in the observational studies. For example, if people with previous GI bleeds were excluded from RCTs, the incidence rates as observed in placebo groups of RCTs would underestimate the incidence rates in the target population (age 50 to 84 years, living in the United States without evidence of cardiovascular disease or stroke).

Some quantitative approaches for benefit and harm assessment explicitly use relative weights for various outcomes.1 RCTs do not provide selection of relative weights for these outcomes (i.e., how important the outcomes are relative to one another as perceived by patients). Additional evidence from surveys using conjoint analysis or other preference-eliciting techniques can provide information on relative weights of outcomes. We searched for studies that elicited patient preferences for MI, stroke (ischemic and hemorrhagic) and GI bleeds to weight the outcomes. No established search filters exist to identify studies on patient preferences and this literature is not indexed consistently. We searched MEDLINE with the PubMed interface using the medical subject headings “patient preference,” “aspirin,” and “cost-benefit analysis,” and used the “related articles” function to search for potential studies. We selected a study that measured the preferences of participants that had not experienced these events (primary prevention population). We relied on a study conducted in the primary prevention population,13 because the relative weights assigned by participants who have not experienced events may be different from those who have experienced such events.

The Appendix shows the details of our data sources for effect estimates, baseline risk of all four outcomes, and relative weights of outcomes.

### Effect Estimates of Aspirin on Benefit and Harm Outcomes

We used the effect estimates from an updated meta-analysis of aspirin for primary prevention for our relevant decisionmaking context.9 This study reported a relative risk (RR) of 0.86 (95% confidence interval [CI], 0.74–1.00) for MI, a RR of 0.87 (95% CI, 0.73–1.02) for ischemic stroke, a RR of 1.35 (95% CI, 1.01–1.81) for hemorrhagic stroke, and a RR of 1.62 for GI bleeds (95% CI, 1.31–2.00) for aspirin compared with placebo or controls using a random effects meta-analysis. Since we did not have access to individual time-to-event patient data, we approximated incidence rate ratios (NNT and NNH approach) and hazard ratios (Gail/NCI approach) using the RRs listed above. A previous meta-analysis of a smaller dataset by the same authors formed the basis of recommendations by the U.S. Preventive Services Task Force on the benefits and harms of aspirin.14

### Estimates of Incidence Rates without Aspirin (Baseline Risks)

We used data from the Atherosclerosis Risk in Communities Study, which is a prospective epidemiologic study conducted in four U.S. communities, to obtain baseline incident rates of MI and stroke without treatment (1987–2001).12 We chose the Atherosclerosis Risk in Communities Study over other large cohorts such as the Framingham Study or the Cardiovascular Health Study because of its random population-based sampling. Since we were unable to find appropriate population-based estimates of GI bleeds in the U.S. population, we relied on the year 2000 estimates from the General Practice Research Database from the United Kingdom, and the Base de Datos para la Investigación Farmacoepidemiológica en Atención Primaria from Spain.15 That report provided estimates for the prevalence of risk factors for severe GI bleeds (age, sex, and prior GI history, i.e., GI pain, mild or severe ulcer) together with incidence rates for severe GI bleeds for each age, sex, and GI history category. Based on those data, we calculated the incidence of severe GI bleeds for the four age categories of the benefit harm assessment for aspirin (45–54, 55–64, 65–74, and 75–84 years) while assuming that people did not take nonsteroidal anti-inflammatory drugs. To estimate the risk of death we relied on 2007 estimates from the U.S. Center for Disease Control.16 Treatment information is not available from the death reports of the Center for Disease Control, so we assumed that the risks of death were for people without treatment. Table 1 shows the baseline incidence rates for untreated men and women. For all outcomes, incidence rates differ according to age categories, and between men and women. Since we did not have hazard rates available, we used the incidence rates (as shown in Table 1) as an approximation of (discrete-time) hazard rates.

Table 1 Incidence rates (per 1,000 person-years) without aspirin based on surveillance data (baseline incidence rates)

Outcomes | Baseline Incidence Rates in Men for Four Age Categories | | | | Baseline Incidence Rates in Women for Four Age Categories
Age Categories | 45–54 | 55–64 | 65–74 | 75–84 | 45–54 | 55–64 | 65–74 | 75–84
MI | 4.0 | 6.2 | 9.3 | 14.0^*^ | 1.2 | 3.0 | 4.7 | 8.2
Major ischemic stroke | 1.2 | 2.5 | 5.6 | 10.8 | 0.9 | 2.0 | 3.6 | 7.5
Major hemorrhagic stroke | 0.2 | 0.4 | 0.8 | 1.6 | 0.1 | 0.3 | 0.5 | 1.1
Major GI bleeds | 1.2 | 2.5 | 4.9 | 8.0 | 0.6 | 1.2 | 2.3 | 3.7
All-cause mortality | 5.0 | 10.0 | 25.0 | 67.0 | 3.0 | 7.0 | 16.0 | 48.0

GI = gastrointestinal; MI = myocardial infarction

* No reliable data was available from the Atherosclerosis Risk in Communities Study for men in age category 75–84 years. To estimate the incidence rate we assumed a 50 percent increase from age category 65–74 years based on similar increases in incidences in age category 65–74 to 75–84 in the Framingham Heart Study and the Cardiovascular Health Study.

### Relative Weights for Outcomes for Gail/National Cancer Institute Approach

Any assumption about preferences may have limitations given the paucity of data on preferences. We identified a single study of 42 participants that reported on patients’ relative weights for various health outcomes with aspirin for primary prevention using a visual analog scale.13 The participants were free of cardiovascular disease and represented subjects from a primary prevention setting. To assign relative weights for various outcomes, we used data on relative weights for these outcomes from this small sample of participants.13 The relative weights for stroke (ischemic and hemorrhagic), MI, and GI bleeds were 0.89, 0.45, and 0.20 respectively and we list them in Appendix Table A-3. We considered the average weight (mean) that participants assigned to these outcomes but, for simplicity, we did not consider the variability of assigned relative weights across participants. We solicited electronic input from our Technical Expert Panel on the incorporation of relative weights for the outcomes identified above. We specifically asked the experts to comment on whether they felt the utility estimates of these outcomes were reasonable.

## Assumptions That Apply to both Quantitative Approaches to Benefit and Harm Assessment

The implementation of the NNT and NNH approach and the Gail/NCI approach required some assumptions. Table 2 describes assumptions that apply to both approaches, except relative weights are not required for the NNT and NNH approach.

Table 2 Assumptions that apply to the quantitative approaches to benefit and harm assessment

Subject | Assumptions^*^
Heterogeneity of Treatment Effects | We assumed that the effect of aspirin on benefit and harm outcomes was the same in all groups (e.g., men and women) on a relative scale based on the results of the 2011 Berger meta-analysis.9
Effects by Gender | We assumed that the effects of aspirin on benefit and harm outcomes did not vary by gender based on the results of the 2011 Berger meta-analysis.9
Effects of Aspirin over Time | We assumed that the relative risk reductions or relative risk increases of aspirin on benefit and harm outcomes did not change over the time horizon of 10 years.
Baseline Incidence Rates over Time | We assumed that the incidence rate of all outcomes without treatment did not change over the time horizon of 10 years.
Measures of Severity | We assumed that all myocardial infarctions were of the same severity, that all strokes were severe, and that all major bleeds were either severe upper or lower GI bleeds to address inconsistent reporting across the trials.
Risk Profiles | We considered different risk profiles of the population, based on characteristics including age and sex. We did not consider additional characteristics such as race, blood pressure, or cholesterol levels because all outcome incidence rates were not available for such profiles.
Applicability of Effects | We assumed RR reductions in benefits or relative risk increases in harms, from the trials, were applicable to the source populations from which estimates of the baseline risks originated.
Relative Weighting of Outcomes (applies only to Gail/National Cancer Institute approach) | To assign relative weights for various outcomes, we used data on preferences for these outcomes from a sample of participants considering aspirin for primary prevention.13 We assumed that the average weight assigned to these outcomes reflected the relative weights of our target population.

GI = gastrointestinal; RR = relative risk

* The assumptions above are common to both approaches, except for weighting of outcomes, which does not apply to the NNT and NNH approach.

## Number Needed to Treat and Number Needed to Harm

We calculated the NNT for MI and ischemic stroke and the NNH for hemorrhagic stroke and GI bleeds (95% CI) with aspirin, by applying the RR for ischemic stroke, hemorrhagic stroke, and GI bleeds from the above meta-analysis9 to the population event rates for these respective outcomes from the observational studies.12 15 (Table 1) We used Visual Rx, version 3.0, an online NNT and NNH calculator provided by the editor of the Airways Group of the Cochrane Collaboration.17,18 We estimated NNTs and NNHs for various age and sex specific categories.

The NNT is the number of person-years of treatment with aspirin needed for one patient to be protected from MI or ischemic stroke, when compared with no aspirin treatment. The NNH is the number of person-years of treatment with aspirin needed for one additional patient to be harmed by a bleeding event, when compared with no aspirin treatment. It can be argued that the terms “number needed to treat to benefit” and “number needed to treat to harm” may be more accurate. We decided to use the more conventional term NNT when we refer to outcomes that are benefits, as opposed to harms. We estimated the NNT and NNH with aspirin in patients with different baseline incidence rates of cardiovascular events and bleeds, as the NNT and NNH varies when aspirin is used in a general population versus highly-selected trial participants.19 To better account for time at risk, we defined the unit of NNT or NNH as the number of person-years of exposure to treatment needed to prevent one event.

### Sensitivity Analysis for Number Needed to Treat and Number Needed to Harm Approach

In a sensitivity analysis, we varied the source of data for baseline incidence rates of cardiovascular events and GI bleeds. We used sex-specific incidence rates from the control groups of trials for MI, stroke, and GI bleeds instead of surveillance data from observational studies (Appendix Table A-4).14

## Gail/National Cancer Institute Approach

The Gail/NCI approach considers multiple patient-important outcomes of a medical intervention and provides profile-specific estimates of the benefit and harm balance. For example, for a patient of a certain age, sex, and with presence or absence of risk factors for the patient-important outcomes, the Gail/NCI approach provides a benefit and harm comparison estimate that can inform decisionmakers (patients, health care providers, policymakers, payers) about whether treatment will increase or decrease patient-important outcomes over a defined period of time, as compared with receiving no treatment.

In a first step we calculated the number of events for each of the four outcomes per 1,000 subjects over 10 years, using baseline incidence rates as described above, and stratified for age and sex. We calculated the number using equation 1:

Nx,p = 1,000*{Ix/(Ix+ M)}*[1−exp{−10(Ix+ M)}] 1

In this equation Nx, p is the number of events (N) for a specific outcome (x) per 1,000 subjects over 10 years in subjects without aspirin (p), Ix is the baseline incidence rate of the event (x), and M is all-cause mortality, which we treated as a competing risk and assumed to be equal for both groups (i.e., RR of 1.0 for aspirin versus placebo).

We then calculated the number of events with aspirin for each of the four outcomes per 1,000 subjects over 10 years, again stratified for age and sex. We used equation 2:

Nx,t = 1,000*{RRx*Ix/(RRx*Ix+ M)}*[1−exp{−10(RRx*Ix+ M)}] 2

In this equation Nx,t is the number of events (N) for a specific outcome (x) per 1,000 subjects over 10 years in subjects with aspirin (t) and RRx represents the RR of aspirin for a specific outcome (x) (derived from the Berger meta-analyses9).

We calculated the difference, Nx, in the number of events (N) for a specific outcome (x) per 1,000 over 10 years in subjects with a certain profile between aspirin users and nonusers using equation 3:

Difference Nx =Nx,p − Nx,t 3

Finally, we put all four outcomes on a single scale using equation 4:

Index(W1, W2, W3)=W1 ∑ Nx_1_ + W2 ∑ Nx_2_ + W3 ∑ Nx_3_ 4

In this equation the index represents the benefit and harm comparison metric as the sum (∑) of differences in events (Nx) for each outcome (1, 2, 3, etc.), using relative weights W, which represent the importance patients attach to certain outcomes in relation to one another. The number of weights depends on how many different weights are used and does not need to equal the number of outcomes. In the original paper about the Gail/NCI approach, for example, the investigators used three different relative weights: 1.0 for very important outcomes, 0.5 for important outcomes, and 0.0 for unimportant outcomes. The index has a negative value if more events are expected with a treatment (in the case of aspirin it would mean more harm than benefit), compared with no treatment or an alternative treatment. The index has a positive value if the treatment reduces the number of events (e.g., more benefit than harm in the case of aspirin). In the main analysis we used the relative weights as described above, followed by sensitivity analyses.

### Sensitivity Analysis for Gail/National Cancer Institute Approach

One critique of quantitative approaches using relative weights is that their selection is arbitrary to some extent, unless there is strong evidence on relative weights from relevant studies (e.g., from primary prevention populations). To address this, we used alternative relative weights. We compared the results using the alternative relative weights to the results incorporating relative weights derived from a study of benefit and harm outcomes of aspirin for primary prevention.13

In the first sensitivity analysis, we assigned equal weights to all outcomes (i.e., “equal preference” for all four outcomes). In the second sensitivity analysis, we assigned relative weights just as the Gail/NCI approach did in their example on tamoxifen for the prevention of breast cancer. In this second analysis, we assigned a weight of 1 for very important outcomes (ischemic or hemorrhagic stroke), 0.5 for important outcomes (MI), and 0 for unimportant outcomes (GI bleeds). Thus, the weights in the second sensitivity analysis mean that we ignored GI bleeds as a harm outcome.

In the third sensitivity analysis, we varied the source of data for baseline incidence rates and used incidence rates from the placebo groups of trials for MI, stroke, and GI bleeds instead of surveillance data. Since a 2006 version of the 2011 Berger meta-analysis reported sex-specific incidence rates, we used this earlier publication as the source of baseline incidence rates.14 We had to use a single baseline incidence rate for each gender since this version did not report baseline incidence rates for different age categories.