# Limitations

Our work has several important limitations. As one would expect, these limitations overlap with the methodological challenges we described above.

A quantitative approach to the assessment of benefits and harms is limited by the quality of reported data. We obtained our estimates for the treatment effects for both benefit and harm outcomes from a meta-analysis of large RCTs of aspirin for primary prevention, which increases our confidence in these estimates. However, the updated meta-analysis included some patients with diabetes and vascular disease who may be at higher risk of cardiovascular events. We could not consider additional characteristics that affect baseline risk such as race, blood pressure, or cholesterol levels because baseline risk for such data were not available from observational studies. Trial incidence rates were comparable for MI and stroke but not for gastrointestinal (GI) bleeds. The observational studies reported a 2-3 times higher risk of GI bleeds than the trials. The possible reasons for this include less rigorous ascertainment of GI bleeds in the trials because it was not a primary outcome in the trials. Heterogeneity in definitions of GI bleeds is possible across trials. Finally, the trials excluded participants at high risk for GI bleeds (e.g., previous GI bleeds due to aspirin or nonsteroidal anti-inflammatory drugs) but the surveillance data included such patients.

For the Gail/NCI approach, we used relative weights obtained from a sample of participants considering aspirin for primary prevention. As described in our previous report,1 it is possible to use NNT and NNH to incorporate weights from different stakeholders to generate relative value NNTs and relative value NNHs, but we did not do this. For the Gail/NCI approach, we assumed that these perceptions of the importance of MI, stroke, and GI bleeds, as expressed on a visual analog scale, reflected their relative weights for these health states. As reflected by the relative weights we used, irreversible outcomes such as stroke are usually assigned higher weights than reversible outcomes such as GI bleeds. Alternative preference elicitation techniques may lead to different valuations, depending on the patient population (primary vs. secondary prevention), the techniques used (time tradeoff vs. standard gamble vs. conjoint analysis), and the outcomes evaluated. Preference elicitation using either the analytic hierarchy process or conjoint analysis may be more suitable for exploring the heterogeneity of treatment preferences, but was beyond the scope of this project. Benefit and harm estimates remain sensitive to assumptions about the heterogeneity of treatment preferences in the population.23 Real heterogeneity in patient preferences would be important to inform the decisionmaking process, but frequently we do not know how much variability among preferences exists. Therefore, we conducted sensitivity analyses using equal relative weights for outcomes and different relative weights for outcomes.

Several other assumptions and inputs merit discussion, and relate to the uncertainty of our results. We did not investigate the possibility that benefit and harm balance varies over time, due to lack of individual-level data. Although researchers have proposed methods for estimating NNT and NNH from survival analysis data, access to only summary data from the meta-analysis prevented such estimation.24 Although we evaluated low-dose aspirin, we included studies of higher doses that researchers tested in large primary prevention trials.