# Future Research

Our report suggests several areas for future research. Our prior report suggests a framework for choosing a quantitative approach or quantitative approaches to benefit and harm assessment. Deciding whether a choice of an approach for a specific decisionmaking context was the right one will require further research and perhaps consensus criteria. Also, end users of systematic reviews and end users of the results of quantitative approaches for benefit and harm assessment should participate in methodological research and evaluations of quantitative benefit and harm assessments to ensure that the evidence generated meets their needs. Future studies should evaluate the reliability and consistency of these quantitative approaches to benefit and harm assessment. Researchers should conduct end-user evaluations to determine the comparative utility and additional advantages of quantitative approaches versus a qualitative assessment of the evidence.

While the literature clearly defines methods for selecting randomized controlled trials (RCTs) for inclusion in a systematic review, the appropriate selection of additional data sources, beyond what is typically included in systematic reviews, needs further development. Future research should address how to select the most valid and applicable incidence data,25 and how to select and rate the quality of preference assessment studies.26 Future studies could improve the reporting and assessment of heterogeneity of treatment effects in systematic reviews.27

Research to understand when a quantitative approach is sufficiently patient-centered is necessary. Although we considered estimates stratified by age and sex, we did not consider additional characteristics such as race, blood pressure, or cholesterol levels, because stratified outcome incidence rates were unavailable for these variables. The challenge will be to balance the need for finely granulated data (e.g., incidence rates stratified for four to five variables) and accurate estimates of incidence. One could consider reporting incidence rates from surveillance studies stratified for these variables. However, limited sample sizes may become a challenge, even in large studies such as the Atherosclerosis Risk in Communities Study. An alternative would be to estimate baseline risks based on risk prediction models such as the Framingham Risk Index. However, outcome predictions may be poorly calibrated if the models were not developed or updated in the population of interest.

It is uncertain how these approaches will perform when outcome data on harms are more sparse and heterogeneous, as is typical in many systematic reviews. Much uncertainty exists about estimates for harms with new, and even newly approved, therapies. For this illustrative example, we did not have a situation in which robust evidence is available for benefit outcomes but little evidence is available for harms, which is typical for many other clinical questions. Such a situation would add a layer of complexity and uncertainty to quantitative approaches to benefit and harm assessments, and is beyond the scope of this report. Future research should investigate methods such as optimal information size to assess explicitly whether statistical power is adequate to detect harms. Future research on quantitative approaches to benefit and harm assessment should investigate how to deal with surrogate outcomes (such as forced expiratory volume in 1 second in chronic obstructive pulmonary disease or glycated hemoglobin in the context of type 2 diabetes mellitus) in benefit and harm assessments. An evaluation of quantitative approaches in the context of surrogate outcomes is needed. In these situations, systematic reviewers and investigators will either have to elicit data on preferences for intermediate outcomes (surrogate outcomes) or make assumptions about linkages between intermediate outcomes and health outcomes (patient-important outcomes).

Future research is needed regarding which methods of preference assessment are most appropriate. We did not evaluate which preference assessment methods are most appropriate; rather we used available relative weights. Future work comparing the elicitation of relative weights for various outcomes using methods such as the analytic hierarchy process or conjoint analysis would also be informative. In the absence of a gold standard method for elicitation of preferences, such research should assess the concordance or discordance of relative weights generated using various methods. Similarly, an important issue is to consider whose preferences a study assesses, and whether there is variability in these preferences across important subgroups or patient profiles.

Future research on these and other quantitative approaches (such as probabilistic simulation and multicriteria decision analysis) should consider appropriate methods of capturing and conveying the uncertainty around the benefit and harm assessment. This uncertainty relates to many of the identified methodological challenges and future research directions described here. Future evaluation should include a comparison of a larger number of quantitative approaches for benefit and harm assessment other than the two presented in this report. In the absence of a gold standard, reliability and consistency in results across various quantitative approaches for assessing benefits and harms may increase our confidence in their results.