# Peer Reviewers

Thank you to the following Peer Reviewers for their time and expert guidance:

- Scott Braithwaite, M.D., M.Sc.
  NYU School of Medicine
  New York, NY
- Wiley Chan, M.D.
  Northwest Permanente
  Kaiser Permanente
  Portland, OR
- Joshua Cohen, Ph.D.
  Tufts University School of Medicine
  Boston, MA
- Robert L. Kane, M.D.
  University of Minnesota
  Minneapolis, MN
- Jonathan Treadwell, Ph.D.
  ECRI Institute Evidence-based Practice Center
  Plymouth Meeting, PA
- Thomas A. Trikalinos, M.D., Ph.D.
  Tufts Medical Center
  Boston, MA
- Fred Wolf, Ph.D.
  University of Washington
  Seattle, WA