# Technical Expert Panel

Thank you to the following Technical Expert Panel members for their time and expert guidance:

- Elie Akl, M.D.
  University of New York Buffalo
  Buffalo, NY
- Wiley Chan, M.D.
  Northwest Permanente, Kaiser Permanente
  Portland, OR
- Robert L. Kane, M.D.
  University of Minnesota
  Minneapolis, MN
- Thomas A. Trikalinos, M.D., Ph.D.
  Tufts Medical Center
  Boston, MA