# Acknowledgments

The team would like to thank Manisha Reuben for her assistance with the formatting of the report and Dr. Parivash Nourjah for her valuable insight throughout the project. We would like to thank Dr. Eric Bass for his thoughtful review, and Eric Vohr for his editorial contribution.