# Discussion

## Summary

Users of systematic reviews are challenged in many ways to make optimal use of complex information. The critical pieces of information in a systematic review are the relative benefits and harms of the treatment options that are compared. Most reviews summarize these separately, and leave it to the user to make sense of it all. Reviewers can either use a qualitative assessment of benefits and harms or consider quantitative approaches. Quantitative approaches can include simpler approaches such as the number needed to treat (NNT) and number needed to harm (NNH) approach. Systematic reviewers can also consider a quantitative combination of benefits and harms, such as the Gail/National Cancer Institute (NCI) approach. Our objectives were to illustrate two quantitative approaches and to evaluate the methodological challenges of applying the two quantitative approaches to benefit and harm assessment in a systematic review.

We illustrated that it is feasible to conduct quantitative benefit and harm assessment in the context of a systematic review of aspirin for primary prevention. Both quantitative approaches showed a comparable excess of gastrointestinal (GI) bleeds caused by aspirin, compared with the number of myocardial infarction (MI) and ischemic strokes prevented. The results appeared slightly favorable for aspirin for primary prevention in the primary analyses and most sensitivity analyses. These results were driven by the relatively higher baseline risks for MI and GI bleeds compared with the lower baseline risks for ischemic stroke and hemorrhagic stroke. The results also were affected by the relatively higher magnitude of treatment effect on the outcomes of hemorrhagic stroke and GI bleeds compared with the smaller effect on the outcomes of MI and ischemic stroke.

The sensitivity analyses that used baseline risks obtained from trials showed that the incidence of some outcomes (GI bleeds) in trials can be different from the incidence observed in observational studies, and that this affects the results of quantitative approaches. Our analyses also showed that since patient-profile-specific baseline risks vary, the characteristics of the target population, such as age and gender, can substantially modify the results of quantitative approaches to benefit and harm assessment. Finally, the sensitivity analyses for the Gail/NCI approach showed that the relative weights used to reflect the importance of different outcomes can have an impact on the results of a quantitative approach to benefit and harm assessment. An important conclusion from these findings, which we will further discuss below, is that assessors of benefits and harms need to carefully choose the three different sources of data, i.e. estimates for treatment effects, baseline risks, and relative weights, and their choices could affect the conclusions drawn from systematic reviews of the corresponding evidence.

The comparison of the two approaches we have chosen for illustration (NNT and NNH, and Gail/NCI) showed that the results for single outcomes (see examples in Table 8) may or may not differ. To ensure comparability, we used identical baseline incidence rates, treatment effect estimates, time horizons, and number of persons treated. We also made the assumptions for both approaches that baseline risks and treatment effects do not change over time. Also, we transformed the typical NNT to the metric used by Gail/NCI (difference in number of events between treated and untreated subjects over a certain period of time) to increase comparability of the actual results.

However, the two approaches have two inherent differences, namely the Gail/NCI approach includes competing risks and patient preferences (relative weights) for outcomes. The examples in Table 8 showed that even if input data for baseline risks and treatment effects are identical, the inclusion of competing risks has a substantial impact on the results when the competing risk is frequent in absolute and relative terms compared with the outcomes of interest (see example 2 in Table 8). We illustrated the impact of different patient preferences in the sensitivity analyses of the Gail/NCI approach. If the relative importance of the relevant types of outcomes differ (as may be the case for GI bleeds and severe stroke), the relative weights used have an impact on the results of a benefit and harm assessment. For the NNT and NNH approach and the Gail/NCI approach, we found little difference in the number of prevented events between the aspirin and placebo groups when the incidence rate for the outcome of interest (e.g., MI) and the competing risk were low. If the competing risk was moderate to high, the simpler NNT and NNH approach did not provide a good approximation of the more complex Gail/NCI approach to estimate the number of prevented or excess events per person year.

## Methodological Challenges

In the following, we discuss important methodological challenges inherent to quantitative benefit and harm assessment in the context of systematic reviews.

### Selection of Data Sources for Treatment Effect and Baseline Risk Estimates

The conduct of a quantitative approach to an assessment of benefits and harms requires integration of data from disparate sources, including individual risks of events without treatment, the effects of treatments on various outcomes, and the relative weights of the outcomes. 1 The latter is discussed in the next methodological challenge. Our results illustrate how the selection of data sources can drive the results of the quantitative approaches.

For instance, if we want to evaluate the balance of benefits and harms for a target population that is quite different from the trial participants, then baseline risks from the placebo arm might not be appropriate. This is illustrated by the effect of varying the baseline risk for GI bleeds in the sensitivity analyses for both the Gail/NCI and NNT and NNH approaches. Some trials excluded subjects with prior GI bleeds and thus minimized the risk for trial participants assigned to placebo. As a consequence, the incidence rates for GI bleeds in the trials were at least 2–3 times lower than in the observational studies that were most representative of the target population of our benefit and harm assessment. In reality, GI bleeds are even more frequent than we assumed in our analysis since some people take nonsteroidal anti-inflammatory drugs, which greatly increase the risk for GI bleeds. Patient characteristics are another key driver of baseline risks. For all four outcomes we considered in our report, there were substantial differences across age and gender categories. Our results illustrate that it is important to stratify the benefit and harm analyses whenever valid estimates for baseline risks for different subgroups are available. This, of course, requires large observational studies or registries. When conducting a quantitative approach to benefit and harm assessment in the context of a systematic review, it will be necessary to go beyond systematic reviews of randomized controlled trials (RCTs) because these RCTs may not provide estimates of baseline risks that are applicable to the target population of the benefit and harm assessment.

We assumed that the treatment effects from trials applied to our target populations. However, one must be careful that, in the presence of heterogeneity of treatment effects, the average treatment effect estimate for the trials may not be entirely applicable to the target population. The 2006 meta-analysis by Berger et al., for example, showed some differences in effects of aspirin in men and women.14 Although there has been some debate about whether gender modifies the effects of aspirin, we did not consider potential effect modification. Another solution would be to conduct another sensitivity analysis to explore whether the conclusions change when we consider different effect estimates for different subgroups.

### Consideration of the Importance of Outcomes (Relative Weights)

The differences between the main results and sensitivity analyses of the Gail/NCI approach illustrate how the assigned relative weights can also have a major impact on results. From the results of the Gail/NCI approach, aspirin is beneficial only when we obtain incidence rates for GI bleeds from the placebo groups of trials or when we ignore GI bleeds (assign a weight of zero). This highlights the importance of considering the source of relative weights that are used in a quantitative approach, and conducting sensitivity analyses to investigate the effect of these relative weights in quantitative approaches.

The issue of relative weights of multiple outcomes is a challenging one for systematic reviewers and end users, whether they report results using a qualitative approach or a quantitative one. For example, considering use of information from NNT and NNH analyses in decisionmaking contexts, weighting many outcomes of varying importance may also be cognitively challenging for decisionmakers. Relative weights may vary across patient profiles. This also highlights the importance of using sensitivity analyses to investigate the effect of these relative weights in quantitative approaches.

### Conveyance of Statistical and Nonstatistical Uncertainty

It is difficult to convey statistical and nonstatistical uncertainty when the intervention may result in either a net harm or a net benefit to the population. With regard to the NNT and NNH approach, the confidence interval (CI) refers to a NNT at one end and to a NNH at the other end. Since the type of quantity referred to by the CI changes, it may be difficult for audiences to understand this information. The communication of statistical uncertainty, such as the CIs around ischemic stroke, which reflect the possibility of both benefit and harm, is challenging. Some have argued that the 95% CIs for NNT or NNH are difficult to describe and should not be reported when there is uncertainty around the possibility of both benefit and harm.20 Considering the Gail/NCI approach, methodological modifications such as probabilistic simulation could incorporate some statistical uncertainty.10 Another challenge to appropriately estimating statistical uncertainty is, as discussed in our previous report in detail, the correlation among outcomes (joint distribution). Most approaches assume marginal distributions (i.e. statistical independence), which is unlikely to be appropriate in many situations. However, little research has been done so far to estimate the impact of joint distributions of outcomes on the estimates of uncertainty (e.g., 95% CI). Finally, nonstatistical sources of uncertainty for benefit and harm assessments exist, including the validity of estimates on treatment effects, baseline risks, and relative weights, or the extent to which the results from scientific studies can be applied to the target population of a benefit and harm assessment.

### Discussion of Principles for Quantitative Approaches for Benefit and Harm Assessment

We compared these quantitative approaches in light of principles that are potentially relevant to the conduct of quantitative approaches for benefit and harm assessment in the context of systematic reviews.1 We summarized these in Table 9. We report our assumptions and the underlying decisionmaking context for both approaches. We used an information preserving approach to present our results using the NNT and NNH person-year approach, and presented results using the number of events prevented or in excess for the Gail/NCI approach. We also showed how assessors of benefits and harms can make the results from the two approaches comparable so that end users can appreciate the differences more easily. We could not adhere to certain principles because of the limitations of underlying data. Neither approach could account for the joint distribution of benefits and harms because of the lack of data. The NNT and NNH approach did not account for competing risk. We were unable to assess the strength of evidence around the benefit and harm comparison metric, or convey uncertainty around such assessment because methods for assessing the strength of evidence around a benefit and harm comparison metric have not been developed.

Table 9 Principles for quantitative approaches for benefit and harm assessment

Principle | Adherence With Number Needed to Treat and Number Needed to Harm Approach | Adherence With National Cancer Institute Approach
Identify the Key Potential Benefits and Harms | We identified benefit and harm outcomes from an updated systematic review. We considered all outcomes commonly considered important in guidelines, trials, and observational studies. We did not interview subjects from a primary prevention setting to ask about outcomes. | We identified benefit and harm outcomes from an updated systematic review. We considered all outcomes commonly considered important in guidelines, trials, and observational studies. We did not interview subjects from a primary prevention setting to ask about outcomes
Report the Characteristics and Assumptions of the Selected Quantitative Approaches | We stated assumptions on page 5, Table 2. | We stated assumptions on page 5, Table 2.
State Whether Preferences Were Considered in the Benefit and Harm Assessment, and if so, Describe how These Were Ascertained, and how Variation in Preferences Would Affect the Assessment | NNT and NNH allow end users to put weights on outcomes. | We used weights from a study for aspirin among primary prevention and considered alternative weights (equal weights). We also used weights of 1.0/0.5/0 as done in the original publication of the Gail/NCI model.
Preserve Information When Reporting on Benefits and Harms | We presented results using the person-year approach. We were unable to account for joint distribution of benefits and harms. We were unable to assess competing risk. | We presented results using excess events. We were unable to account for joint distribution of benefits and harms. This considers competing risk of mortality.
Convey Statistical Uncertainty and Uncertainty in the Strength of the Evidence | Table 3 and Table 4 convey statistical uncertainty on outcomes through 95% CI. | There are no estimates of uncertainty (such as 95% CI), but we could assess the probability of the index being positive or negative using Markov modeling.10
State how Decisions About Comparisons, Outcomes, Baseline Risks, and Time Horizons Were Made to Increase Transparency and Traceability | See the decisionmaking context on page 2, data sources in Appendix. | See the decisionmaking context on page 2, data sources in Appendix.

CI = confidence interval; NCI = National Cancer Institute; NNH = number needed to harm; NNT = number needed to treat

### Choice of Quantitative Approaches

Overall, it is easier to use simpler approaches directly from the results generated from meta-analysis. However these simpler approaches may also have strong assumptions, and therefore defer the task of weighting outcomes for decisionmakers. In contrast, more complex approaches which generate a benefit and harm comparison metric require additional data on baseline risk and relative weights. Both complex and simpler approaches may include the inherent assumption about the applicability of these data to the intended target population. One could base the selection of a quantitative approach on the specific decisionmaking context, the number of relevant outcomes, and the desire for a single benefit and harm comparison metric. One could also pursue a more data-driven approach where one interprets the results for the different outcomes separately (e.g., using NNT and NNH) and only combines them using a more complex approach if the benefit and harm comparison does not clearly favor one of the treatment options. However, such a data-driven approach may confront researchers with arbitrary decisions because in many instances there may not be a clear winner, particularly if one considers patient profiles.

The Gail/NCI approach shows a potential advantage over the NNT and NNH approach in that it not only combines the information from the three data sources but also combines the results in a single number, which we call a benefit and harm comparison metric. If one agrees with the inputs (estimates on treatment effects, baseline risks, and relative weights), the interpretation is relatively straightforward. In our example, a positive summary index means that harms exceed benefits, and a negative number means that benefits exceed harms.

With the NNT and NNH approach, it is more difficult to draw a conclusion because it does not weight the outcomes and it lacks a benefit and harm comparison metric to put the results on a single scale. For the example of aspirin, the NNH estimates are so much lower than the NNT estimates that one may still conclude that aspirin is likely to cause more harm than benefit. If the estimates for NNH and NNT were more similar, the interpretation would become more challenging.

Finally, the examples in Table 8, where we directly compared the two approaches, showed that different approaches may or may not yield similar results. When, for example, competing risks are moderate or high (as in our example 2, where the risk for mortality was about 5 times as high as the incidence rates for MI) one should choose those approaches that consider competing risks.

When planning a quantitative approach to a benefit and harm assessment for a specific decisionmaking context, it is critically important to carefully consider potential data sources, the selection of the quantitative approach, and the planning of sensitivity analyses. One could consider more complex approaches like the Gail/NCI approach if there are multiple outcomes, if there are important competing risks, and if the relative importance of outcomes is likely to differ. The Gail/NCI way of combining the three sources may be easier to describe than the NNT and NNH approach. Interpreting several NNTs and NNHs for decisionmaking requires an informal combination of NNT and NNH. Finally, planning for specific quantitative approaches in the context of systematic reviews has implications for both time and resources (financial and personnel with different types of expertise).

## Clinical Implications

Our findings demonstrate the feasibility and utility of such methods, but are not clinically directive. However, we believe a brief discussion, comparing our findings to clinically focused work, may be useful. Earlier analysis by the United States Preventive Services Task Force (USPSTF) in 2009 showed a benefit of aspirin for people with moderate to high cardiovascular disease risk.21 However, the analysis assumed a relative risk reduction of about 32 percent in MI from a 2006 meta-analysis21 of six primary prevention trials.14 The updated meta-analysis (same authors) reported a smaller relative risk reduction for MI of about 14 percent9 using the relative risk method. A major difference between the work by the USPSTF and our work is the specific decisionmaking context, and thus the aim of the benefit and harm assessment. A distinction needs to be made between benefit and harm assessment on a population level versus a benefit and harm assessment for individual subjects. Our target of inference was a United States population, age 50 to 84 years without evidence of cardiovascular disease or stroke. We did not intend to make any recommendations, but assessed the benefits and harms of aspirin on a population level. Therefore, we chose to use population-based outcome data from the population-based Atherosclerosis Risk in Communities Study. The USPSTF statement, however, provides recommendations for individuals in practice settings where risk prediction models provide better guidance than population-based statistics. The USPSTF proposed to use risk prediction equations to estimate the absolute 10-year risks of MI.

For clinical practice, the suggestions of the USPSTF to use risk prediction models is attractive because one can estimate the baseline risk for individual subjects. An important caveat, however, is that the performance of risk prediction models depends largely on the specific population where they are used.11 Even a widely established model like the Framingham prediction model has limited applicability across different populations unless the model is recalibrated carefully.22 In summary, the differences between the benefit and harm assessments made by the USPSTF and our work highlights the importance of clarity of purpose when conducting a benefit harm and assessment because it affects the selection of appropriate sources of evidence. Furthermore, although the USPSTF analysis used similar baseline risk estimates, it did not consider death as a competing risk or incorporate relative weights and could not explore the effect of a gradient in relative weights across outcomes.