# Conclusion

The assessment of benefits and harms requires careful selection and integration of data from disparate sources, including baseline risks of events without treatment, the effects of treatments on various outcomes, and relative weights of these outcomes. We have illustrated that quantitative approaches are feasible in a specific decisionmaking context—using data from a systematic review of aspirin for primary prevention. Quantitative approaches can yield different results even if input data for baseline risks and treatment effects are identical. Quantitative approaches can be particularly valuable in demonstrating how the expected balance of benefits and harms depends on assumptions about the relative weights of different outcomes.