# Details of Our Data Sources for Effect Estimates, Baseline Risk of All Four Outcomes, and Weights of Outcomes

Table A-1 Treatment effects of aspirin for the primary prevention of cardiovascular events

Treatment Effect | RR [95% CI]1,*
MI | 0.86 [0.74,1.00]
Ischemic stroke | 0.87 [0.73,1.02]
Hemorrhagic stroke | 1.35 [1.01,1.81]
Major bleeds | 1.62 [1.31,2.00]

* This meta-analysis included the nine major primary prevention trials: British Doctors’ Trial (BMD), Physicians’ Health Study (PHS), Thrombosis Prevention Trial (TPT), Hypertension Optimal Treatment (HOT) study, Primary Prevention Project (PPP), Women’s Health Study (WHS), Atherosclerosis Trial [AAAT], Japanese Primary Prevention of Atherosclerosis with ASA for Diabetes, and the Prevention of progression of arterial disease and diabetes (POPADAD) trial. The mean age of the participants ranged from 54.6 years in the Women’s Health Study to 65 years in the JPAD trial. Most of the trials used low-dose daily aspirin except for the British Doctors study which evaluated 500 mg of daily aspirin and PHS which evaluated 325 mg of aspirin every alternate day and WHS which evaluated 100 mg every alternate day. The mean followup duration ranged from 3.6 years in the Primary Prevention Project to 10.1 years in the Womens Health Study.)

CI = confidence interval, MI = Myocardial infarction, RR = Relative risk

Table A-2 Baseline risk

Indicator (Incidence Rate) | Source (Year)
MI | ARIC2 Community Surveillance Component (1987–89, 1990–92, 1996–98) Baseline n=4,000 aged 45–64 (total sample: 15,792). Hospitalized MI incidence currently documented in men and women aged 35–84. If population-based estimates are unavailable, data extracted from primary care setting
Major ischemic stroke | ARIC Cohort Component2
Major hemorrhagic stroke | ARIC Cohort Component2
Major GI bleeds4 | GPRD: population-based database in the U.K. (approx. 3 million patients)3
All-cause mortality | U.S. Vital Statistics5

MI = Myocardial infarction, RR = Relative risk, GI = Gastrointestinal, U.K. = United Kingdom, U.S. = United States, ARIC = Atherosclerosis Risk in Communities, GPRD = General Practice Research Database

Table A-3 Relative weights for outcomes6

Weights (descending severity) | Perceived severity | Complement ( Weights used)
Major stroke | 0.11 | 0.89
MI | 0.55 | 0.45
Major GI bleeds | 0.80 | 0.20

MI = Myocardial infarction, GI = Gastrointestinal

Table A-4 Source of incidence rates (per 1,000 person-years) without aspirin based on control event rates in the trials for Sensitivity analysis7

| Incidence rates in Men | Incidence rates in Women
MI | 5.6 | 1.0
Major ischemic stroke | 2.1 | 1.1
Major hemorrhagic stroke | 0.3 | 0.2
Major GI bleeds | 0.9 | 0.5
All-cause mortality | 7.9 | 3.4

The incidence rate was estimated by dividing the number of events in the control arm by the person years of followup in the control arm which equals the total number of participants in the control arm and the mean length of followup for the trial= ( n/N * Mean followup duration of the trial in years)

MI = Myocardial infarction, GI = Gastrointestinal

## References

1 Berger JS, Lala A, Krantz MJ, et al. Aspirin for the prevention of cardiovascular events in patients without clinical cardiovascular disease: a meta-analysis of randomized trials. Am Heart J. Jul. 2011;162(1):115-24.e2. [pmid: 21742097].
2 ARIC/NHLBI Surveillance Data, Incidence and prevalence: 2006 chart book on cardiovascular and lung diseases, Table 2.1, p.6 and Ibid, Table 4.6, p. 42.
3 Garcia Rodriguez LA, Perez Gutthann S. (1998). Use of the uk general practice research database for pharmacoepidemiology. Br J Clin Pharmacol. May. 1998;45(5):419-25. [pmid: 9643612].
4 Hernández-Díaz S, García Rodríguez LA. Cardioprotective aspirin users and their excess risk of upper gastrointestinal complications. BMC Med. Sep. 20. 2006;4:22. [pmid: 16987411].
5 National Vital Statistics System. 2012. Retrieved from Centers for Disease Control and Prevention Web site. http://www.cdc.gov/nchs/nvss.htm. Accessed October 22, 2012.
6 Man-Son-Hing M, Laupacis A, O’Connor AM, et al. Patient preference-based treatment thresholds and recommendations: a comparison of decision-analytic modeling with the probability-tradeoff technique. Med Decis Making. 2000;20(4):394-403. [pmid: 11059472].
7 Berger JS, Roncaglioni MC, Avanzini F, et al. Aspirin for the primary prevention of cardiovascular events in women and men: a sex-specific meta-analysis of randomized controlled trials. JAMA. Jan. 18. 2006;295(3):306-13. [pmid: 16418466].