# Acronyms/Abbreviations

Acronym: Definition
AHRQ: Agency for Healthcare Research and Quality
CI: Confidence interval
Gail/NCI: Gail/National Cancer Institute
GI: Gastrointestinal
MI: Myocardial Infarction
NNH: Number needed to harm
NNT: Number needed to treat
RCTs: Randomized controlled trials
RR: Relative Risk