# Results

The results are organized by aim.

## Description of the Database (Aim 1)

Out of the 4848 reviews in the Cochrane Library, 1919 had at least one collection of studies where the primary Cochrane reviewers performed a meta-analysis of binary data. Ninety-eight reviews identified 1381 candidate pairs of binary meta-analyses with at least seven RCTs reporting on both outcomes and having at least two events and 10 patients per arm. The vast majority were not of the mutually exclusive or is-subset-of type, but rather reported rates of outcomes such as heart attack and stroke without their co-occurrence rate. In such cases, the full combination of outcomes was not exactly recoverable and so did not meet our inclusion criteria. After applying all of the inclusion and exclusion criteria, 29 reviews contributing 45 eligible independent pairs or triplets of binary meta-analyses were eligible: 38 instances pertained to pairs of outcomes where the first outcome was a subset of the second outcome (Table 10, topic numbers 1 through 38); in five instances the pair of outcomes were mutually exclusive (Table 11, topic numbers 39 through 43); and for two topics we identified two triplets of outcomes with an is-subset-of relationship (Table 12, topic numbers 44 and 45). A single Cochrane review on medications for preventing post-operative nausea and vomiting contributed 12 independent pairs of outcomes that have an is-subset-of relationship.

Table 10 Thirty-eight pairs of outcomes having an is-subset-of relationship

# | Category | Review (Comp #) | Topic | Comparison | O1 | O1 | O2 | O2 | O1 & O2 | Only O1 | Only O2
| | | | | ID#^*^ | Description | ID#^*^ | Description | K (N) | K (N) | K (N)
1 | Card | CD004587 (1)17 | Drug-eluting stents versus bare metal stents for angina or acute coronary syndromes | Paclitaxel-eluting stents versus bare metal stents | 1, 2 | Major adverse cardiac events by 6 months | 2, 2 | Major adverse cardiac events by 12 months | 15 (6325) | 6 (1978) | 1 (605)
2 | Card | CD004587 (1)17 | Drug-eluting stents versus bare metal stents for angina or acute coronary syndromes | Sirolimus-eluting stents versus bare metal stents | 1, 1 | Major adverse cardiac events by 6 months | 2, 1 | Major adverse cardiac events by 12 months | 16 (4521) | 5 (1141) | 4 (1084)
3 | Gen | CD002296 (5)18 | Prevention of NSAID-induced gastroduodenal ulcers | Misoprostol (800 μg/day) versus placebo | 8, 3 | Dropout due to side events | 9, 3 | Dropout for any reason | 10 (11798) | 2 (1095) | 1 (277)
4 | Ped | CD001145 (6)19 | Late postnatal corticosteroids for chronic lung disease in preterm infants | Late postnatal corticosteroids versus control | 9, 1 | Cerebral palsy | 11, 1 | Death or cerebral palsy | 11 (777) | 0 | 0
5 | Ped | CD000509 (1)20 | Inhaled nitric oxide for respiratory failure in preterm infants | Nitric oxide versus control | 3, 1 | Bronchopulmonary dysplasia among survivors at 36 weeks | 4, 1 | Death or bronchopulmonary dysplasia at 36 weeks | 8 (958) | 0 | 0
6 | Ped | CD000551 (3)21 | Ursodeoxycholic acid for primary biliary cirrhosis | Ursodeoxycholic acid versus nothing | 1, 1 | Mortality | 2, 1 | Mortality or liver transplantation | 15 (1275) | 0 | 1 (28)
7 | Ped | CD001533 (1)22 | Corticosteroid therapy for nephrotic syndrome in children | Increased versus standard dose of prednisone | 4, 3 | Number with frequent relapses | 2, 3 | Number with any relapse | 7 (512) | 0 | 0
8 | Ped | CD003665 (1)23 | Vitamin E for prevention of morbidity and mortality in preterm infants | Vitamin E versus placebo/no vitamin E | 37, 1 | Severe retrolental fibroplasia/retinopathy of prematurity | 33, 1 | Any retrolental fibroplasia/retinopathy of prematurity | 8 (1666) | 0 | 1 (51)
9 | Ob Gyn | CD001396 (1)24 | SSRIs for premenstrual syndrome | SSRIs versus placebo | 11, 1 | Withdrawal due to adverse events | 11, 2 | Withdrawal for any reason | 32 (3486) | 0 | 5 (247)
10 | Ob Gyn | CD001750 (1)25 | GnRH antagonists for assisted reproductive technology | GnRH antagonist versus long course GnRH agonist | 2, 1 | Ongoing pregnancy | 3, 1 | Clinical pregnancy | 45 (7209) | 4 (638) | 17 (2195)
11 | Ob Gyn | CD005214 (1)26 | Depot medroxyprogesterone versus norethisterone oenanthate for long-acting progestogenic contraception. | Depot medroxyprogesterone versus norethisterone oenanthate | 1, 1 | Discontinuation at 12 months | 1, 2 | Discontinuation at 24 months | 14 (2776) | 1 (400) | 0
12 | Ob Gyn | CD004454 (1)27 | Antenatal corticosteroids for accelerating fetal lung maturation for women at risk of preterm birth | Corticosteroids versus placebo/no treatment | 6, 1 | Neonatal deaths | 4, 1 | Fetal or neonatal deaths | 18 (4140) | 5 (513) | 0
13 | Ob Gyn | CD001141 (3)28 | Support for breastfeeding mothers | All forms of breastfeeding support versus usual care | 1, 3 | Stopping any breastfeeding by 3 months | 1, 5 | Stopping any breastfeeding by 6 months | 16 (5304) | 4 (1247) | 2 (664)
14 | Ob Gyn | CD001141 (6)28 | Support for breastfeeding mothers | Professional breastfeeding support versus usual care | 1, 3 | Stopping any breastfeeding by 3 months | 1, 6 | Stopping any breastfeeding by 6 months | 9 (3539) | 1 (507) | 1 (849)
15 | Ob Gyn | CD000014 (1)29 | Amnioinfusion for meconium-stained liquor in labour | Amnioinfusion versus no amnioinfusion | 6, 1 | Caesarean for fetal distress | 7, 1 | Caesarean overall | 11 (3380) | 0 | 3 (615)
16 | InfD | CD002848 (2)30 | Rotavirus vaccine for preventing diarrhoea | Rhesus rotavirus vaccines versus control | 2, 1 | Severe episodes of rotavirus diarrhoea | 1, 1 | All episodes of rotavirus diarrhoea | 20 (13305) | 0 | 9 (2699)
17 | InfD | CD002848 (2)30 | Rotavirus vaccine for preventing diarrhoea | Bovine rotavirus vaccines versus control | 2, 2 | Severe episodes of rotavirus diarrhoea | 1, 2 | All episodes of rotavirus diarrhoea | 17 (5283) | 0 | 7 (1640)
18 | InfD | CD003774 (1)31 | Antivirals for preventing CMV disease in solid organ transplant recipients | Antiviral prophylaxis versus placebo/no treatment | 1, 2 | CMV syndrome | 1, 1 | All symptomatic CMV disease | 19 (1981) | 0 | 8 (411)
19 | InfD | CD002898 (1)32 | Antivirals and other therapies for HSV epithelial keratitis | Acyclovir versus idoxuridine | 10, 1 | Healing by 7 days | 10, 2 | Healing by 14 days | 9 (476) | 0 | 1 (75)
20 | InfD | CD002898 (3)32 | Antivirals and other therapies for HSV epithelial keratitis | Interferon/nucleoside antiviral versus control | 7, 1 | Healing by 7 days | 7, 2 | Healing by 14 days | 11 (606) | 0 | 2 (138)
21 | Neph | CD003897 (1)33 | IL2Ra for kidney transplant recipients | IL2Ra versus placebo/no treatment | 3, 6 | Graft loss censored for death with functioning graft | 4, 4 | Acute rejection: clinically suspected or biopsy proven | 30 (5582) | 0 | 1 (44)
22 | Neph | CD003897 (2)33 | IL2Ra for kidney transplant recipients | IL2Ra versus antithymocyte globulin | 3, 3 | Graft loss censored for death with functioning graft | 2, 3 | Graft loss or death with a functioning graft | 12 (1394) | 0 | 0
23 | Neph | CD003961 (1)34 | Tacrolimus versus cyclosporin for kidney transplant recipients | Tacrolimus versus cyclosporin | 6, 3 | Mortality | 5, 3 | Total graft loss (with death) | 14 (2604) | 0 | 0
24 | Neph | CD004293 (1)35 | Immunosuppression for idiopathic membranous nephropathy in adults with nephrotic syndrome | Immunosuppressive therapy versus placebo/no treatment | 2, 1 | Dialysis or transplantation | 3, 1 | Dialysis, transplantation or death | 10 (620) | 0 | 0
25 | MH | CD003197 (3)36 | Low dosage TCA for depression | Low dosage TCA versus placebo | 3, 2 | Depression improved by 2 weeks | 3, 3 | Depression improved by 4 weeks | 11 (735) | 1 (25) | 2 (235)
26 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Ondansetron versus placebo | 1, 33 | Nausea | 3, 28 | Nausea or vomiting | 132 (16967) | 53 (10238) | 18 (990)
27 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Droperidol versus placebo | 1, 17 | Nausea | 3, 14 | Nausea or vomiting | 102 (8305) | 33 (2199) | 22 (1086)
28 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Dexamethasone versus placebo | 2, 14 | Vomiting | 3, 8 | Nausea or vomiting | 70 (5807) | 24 (2276) | 4 (173)
29 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Metoclopramide versus placebo | 1, 29 | Nausea | 3, 25 | Nausea or vomiting | 72 (3685) | 18 (978) | 14 (684)
30 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Granisetron versus placebo | 2, 24 | Vomiting | 3, 18 | Nausea or vomiting | 54 (4206) | 20 (1554) | 2 (93)
31 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Tropisetron versus placebo | 4, 39 | Rescue antiemetic | 3, 40 | Nausea or vomiting | 28 (2484) | 12 (1296) | 4 (480)
32 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Dolasetron versus placebo | 1, 15 | Nausea | 3, 12 | Nausea or vomiting | 14 (2864) | 2 (1070) | 1 (52)
33 | Surg | CD004125 (1)37 | Prevention of postoperative nausea and vomiting | Hyoscine versus placebo | 1, 22 | Nausea | 3, 20 | Nausea or vomiting | 15 (1040) | 7 (411) | 1 (32)
34 | Surg | CD004125 (3)37 | Prevention of postoperative nausea and vomiting | Droperidol versus granisetron | 2, 53 | Vomiting | 3, 42 | Nausea or vomiting | 24 (1008) | 6 (264) | 0
35 | Surg | CD004125 (3)37 | Prevention of postoperative nausea and vomiting | Droperidol versus metoclopramide | 1, 47 | Nausea | 3, 46 | Nausea or vomiting | 32 (964) | 9 (209) | 5 (238)
36 | Surg | CD004125 (3)37 | Prevention of postoperative nausea and vomiting | Granisetron versus metoclopramide | 2, 71 | Vomiting | 3, 57 | Nausea or vomiting | 14 (388) | 3 (70) | 1 (12)
37 | Surg | CD004125 (3)37 | Prevention of postoperative nausea and vomiting | Dexamethasone versus ondansetron | 4, 15 | Rescue antiemetic | 3, 22 | Nausea or vomiting | 7 (304) | 0 | 0
38 | Surg | CD004603 (2)38 | Perioperative ketamine for acute postoperative pain | Adverse effects | 1, 1 | Nausea | 1, 3 | Nausea or vomiting | 26 (1283) | 0 | 14 (702)

The number of people experiencing the first outcome is a subset of the number of people experiencing the second outcome.

Card: cardiology; CMV: cytomegalovirus; Gen: general medicine; GnRH: gonadotrophin-releasing hormone; HSV: herpes simplex virus; InfD: infectious disease; MH: mental health; Neph: nephrology; NSAID: nonsteroidal anti-inflammatory drugs; Ob Gyn: obstetrics/gynecology; Ped: pediatrics; SSRI: Selective serotinine reuptake inhibitors; Surg: surgery; TCA: Tricyclic antidepressants. The following are column keys: Comp #: comparison number in the Cochrane review; K: number of studies; N: number of participants; O1|O2: outcome 1 | 2.

* ID#: The first number is the number of the outcome in the respective Cochrane review; the second number is the number of the subgroup.

Table 11 Five pairs of mutually exclusive outcomes

# | Category | Review (Comp #) | Topic | Comparison | O1 | O1 | O2 | O2 | O1 & O2 | Only O1 | Only O2
| | | | | ID#^*^ | Description | ID#^*^ | Description | K (N) | K (N) | K (N)
39 | Gen | CD001431 (1)39 | Decision aids for people facing health treatment or screening decisions | Decision aids versus usual care | 4, 1 | Patient controlled decision making | 4, 3 | Practitioner controlled decision making | 11 (1928) | 0 | 1 (171)
40 | Ped | CD004000 (1)40 | Intravenous immunoglobulin for Kawasaki disease in children | Intravenous immunoglobulin versus control | 1, 1 | Development of chest aortic aneurysms (0 to 30 days) | 1, 2 | Development of chest aortic aneurysms (31 to 60 days) | 10 (1024) | 0 | 0
41 | Ob Gyn | CD003766 (3)41 | Continuous support for women during childbirth | Continuous support versus usual care | 3, 1 | Spontaneous vaginal birth | 4, 1 | Caesarean birth | 14 (13093) | 0 | 1 (420)
42 | Ob Gyn | CD004659 (1)42 | Antiplatelet agents for primary prevention of preeclampsia and its complications | Antiplatelet versus control | 12, 2 | Perinatal deaths | 12, 1 | Stillbirths or miscarriages | 31 (24514) | 3 (6445) | 16 (7964)
43 | Ob Gyn | CD004667 (2)43 | Midwife-led versus other models of care for childbearing women | Midwife-led versus other models of care | 9, 2 | Spontaneous vaginal birth | 7, 2 | Caesarean birth | 9 (9183) | 0 | 2 (971)

Outcomes 1 and 2 are mutually exclusive. Gen: general medicine; Ob Gyn: obstetrics/gynecology; Ped: pediatrics.

The following are column keys: Comp #: comparison number in the Cochrane review; K: number of studies; N: number of participants; O1|O2: outcome 1 | 2.

* ID#: The first number is the number of the outcome in the respective Cochrane review; the second number is the number of the subgroup.

Table 12 Two triplets of outcomes having an is-subset-of relationship

# | Category | Review (Comp #) | Topic | Comparison | O1 | O1 | O2 | O2 | O3 | O3
| | | | | ID#^*^ | Description | ID#^*^ | Description | ID#^*^ | Description
44 | MH | CD001026 (1)44 | Antidepressants plus benzodiazepines for major depression | Antidepressants plus benzodiazepines versus antidepressants | 7, 1 | Depression improved by 1 week | 7, 2 | Depression improved by 2 weeks | 7, 3 | Depression improved by 4 weeks
45 | Card | CD002230 (5)45 | Phosphodiesterase III inhibitors for heart failure | Phosphodiesterase III inhibitors versus control | 3, 1 | Sudden death | 2, 1 | Cardiac death | 1, 1 | Total mortality

The number of people experiencing the first outcome is a subset of the number of people experiencing the second outcome, which in turn is a subset of those experiencing the third outcome. MH: mental health; Card: cardiology.

The following are column keys: Comp #: comparison number in the Cochrane review; O1|O2|O3: outcome 1 | 2 | 3.

* ID#: The first number is the number of the outcome in the respective Cochrane review; the second number is the number of the subgroup.

For the first topic (number 44) a total of 10 RCTs with a total of 599 people provided data on all three outcomes. For the second topic (number 45), 13 RCTs (7337 people) provided data for all three outcomes, two RCTs (469 people) provided data only for the first and the third outcome, one RCT (230 people) provided data only for the second and the third outcome, and three RCTs (262 people) provided data only for the third outcome.

The 45 topics pertain to a variety of clinical questions in cardiology (n=3), general medicine (n=2), pediatrics (n=6), obstetrics and gynecology (n=10), infectious diseases (n=5), nephrology (n=4), mental health (n=2) and surgery (n=13). In total, 1473 RCTs (258,675 randomized patients) were included in the database. The median number of RCTs per topic was 18, ranging from 7 to 203. The median total number of participants per topic was 3733 (range from 304 to 38,923). Twenty one topics had at least 20 RCTs, and 7 topics had at least 50 RCTs. Across the 45 topics, between 62 percent and 100 percent of RCTs reported on all outcomes. In 9 topics all RCTs reported data for all outcomes.

## Empirical Comparisons (Aim 2)

We first describe results with meta-analysis models that use the normal approximation. Subsequently, we present the corresponding analyses with models that use the binomial or multinomial distribution to model the underlying data.

### Normal Approximation Methods

#### Corrections for Singularity in Covariance Matrices

Eighty studies in 21 topics, all in outcomes having an is-subset-of-relationship, had singular covariance matrices. Based on the formulas in the Appendix, it is obvious that singular covariance matrices can arise when the number of people experiencing the first outcome is exactly the same as the number experiencing the second outcome. For example, in topic 2, comparison between sirolimus-eluting and bare metal stents for acute cardiac disease, in the STRATEGY trial, the number of major cardiac events was the same at 6 months and 12 months, that is, no additional events were observed between 6 and 12 months.46,47 The multivariate analyses used a ridge regression approach when at least one study had a singular covariance matrix. Table 13 shows the ridge regression factors (regularizing constants or regularizers) used. Using larger values or excluding the studies with singular covariance matrices from the analysis yields very similar results to those presented here (not shown). Figure 1 shows a plot of the meta-analysis means versus a range of values for the regularizing constant ɛ_ridge_ for topic 2.

Table 13 Topics with RCTs with singular covariance matrices

Topic | Number of RCTs with singular matrices | Number of RCTs reporting two or more outcomes | Total number of RCTs | ɛ _ridge_
2 | 1 | 16 | 25 | 10.2
3 | 1 | 10 | 13 | 15.8
4 | 1 | 11 | 11 | 2.5
6 | 5 | 15 | 16 | 4.8
9 | 2 | 32 | 37 | 2.5
10 | 1 | 45 | 66 | 23.4
12 | 1 | 18 | 23 | 6.2
22 | 2 | 12 | 12 | 4.3
23 | 1 | 14 | 14 | 2.7
24 | 4 | 10 | 10 | 4.4
26 | 18 | 132 | 203 | 70.8
27 | 14 | 102 | 157 | 77.6
28 | 1 | 70 | 98 | 7.6
29 | 10 | 72 | 104 | 32.4
31 | 1 | 28 | 44 | 4.1
32 | 3 | 14 | 17 | 10.0
33 | 1 | 15 | 23 | 3.2
34 | 1 | 24 | 30 | 3.4
35 | 4 | 32 | 46 | 6.5
38 | 7 | 26 | 40 | 14.8
45 | 1 | 16 | 17 | 575.4

The correction factors used in the ridge regression approach were selected using an objective heuristic (described in the Appendix). The remaining topics did not have any RCTs with singular covariance matrices.

Figure 1 Plot for choosing the regularizing constant for the ridge regression (example, topic 2)

The suggested value of the regularizing constant uses a heuristic that examines the smoothed numerical derivatives with respect to ɛ_ridge_ of the meta-analysis means and of the trace and determinant of the inverse covariance matrix for the means. An investigator examined such plots for all topics listed in Table 13; in all cases the ɛ_ridge_ value suggested by the heuristic was deemed acceptable. An infinitely large value for ɛ_ridge_ is equivalent to excluding studies with singular covariance matrices from the multivariate meta-analysis.

Figure 1 plots (as an example) the meta-analysis means versus a range of values for the regularizing constant for topic 2. The used and suggested regularizing constants in this example were both 10.2.

Figure 2 shows summary results with univariate and multivariate (bivariate) meta-analyses using the normal likelihood (in Appendix Table 1 we give the same results in tabular form). Figure 3 shows the respective results for topics 44 and 45, which have three outcomes with an is-subset-of relationship (the data in the figure are reported in tabular form in Appendix Table 2). Generally, the point estimates and the lengths of the confidence intervals are comparable using the two methodologies.

Figure 2 Summary estimates from univariate and bivariate meta-analysis in topics 1 through 43 (REML random effects, normal approximation)

Filled circles are results from bivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ̂_1_: meta-analysis mean for the first outcome; θ̂_2_: meta-analysis mean for the second outcome. For topics 1 through 38 those experiencing the first outcome are a subset of those experiencing the second outcome. For topics 39 through 43, the two outcomes are mutually exclusive.

Figure 2 plots a comparison of the summary estimates from univariate and bivariate meta-analysis in topics 1 through 43, using the normal approximation. Overall, the point estimates and the lengths of the confidence intervals are comparable with the two methodologies.

Figure 3 Summary estimates from univariate and trivariate meta-analysis in topics 44 and 45 (REML random effects, normal approximation)

Filled circles are results from trivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ̂_1_ through θ̂_3_: meta-analysis means for the first through third outcome.

Figure 3 plots a comparison of the summary estimates from univariate and trivariate meta-analysis in topics 44 and 45, using the normal approximation. Overall, the point estimates and the lengths of the confidence intervals are comparable with the two methodologies.

Some exceptions are notable. The most prominent is in topic 30, comparison of granisetron versus placebo for postoperative nausea and vomiting, where the summary odds ratio for “nausea or vomiting” (the second outcome) is more extreme in bivariate meta-analysis (0.18 95% CI 0.14 to 0.22) than in univariate meta-analysis (0.24, 95% CI 0.20 to 0.30). The summary odds ratios for the first outcome (“vomiting”) are 0.25 (0.20 to 0.30) and 0.24 (0.19 to 0.30), respectively. Nevertheless, even this numerical difference would not change conclusions on the effectiveness of granisetron. Topic 10 differs qualitatively for outcome 1, in that one of the confidence intervals includes the null value of 1 whereas the other does not. A similar comment applies to topics 15 and 41 for outcome 2. However, the actual numerical differences are very small. In all likelihood, systematic review conclusions that are based on the meta-analyses examined here would be extremely similar with either method of analysis.

As evident from Figure 2, Figure 3 and the Appendix tables, multivariate and univariate analyses yielded confidence intervals of different length. Across all 45 topics, the ratio of the standard errors with multivariate versus univariate analyses ranged between 0.6 and 1.4 for the first outcome (median ratio 0.99) and between 0.8 and 1.3 for the second outcome (median ratio 1.00). The ratio was 1.1 for the third outcome in topics 44 and 45. Compared with univariate analyses, multivariate analyses yielded smaller standard errors (ratio of standard errors less than 1) in 25 and 22 topics for the first and second outcome, respectively.

#### Between-Outcome Relative Odds Ratios (Differences in Treatment Effects Between Outcomes)

It is instructive to calculate differences in the meta-analysis means. As discussed in the Methods section, such differences are log relative odds ratios for experiencing the first versus the second outcome in the treatment versus the comparator group. Depending on the context of the topic and the definitions of the outcomes, these differences may or may not be helpful. For example, if the first outcome is “alive at 12 months” and the second outcome is “alive at 6 months,” the difference in the outcomes can inform on whether the treatment log odds ratio differs between earlier and later time points. However, it is unclear whether the relative odds ratio is helpful or informative for pairs of outcomes such as “spontaneous vaginal birth” and “caesarean birth.” Regardless, forming differences between the outcomes presents an opportunity for technical observations and comments.

Figure 4 shows the relative treatment effects for univariate and bivariate meta-analyses in topics 1 through 43. Figure 5 shows the corresponding results for topics 44 and 45. The tabular representations are in Appendix Tables 1 and 2. Univariate and multivariate meta-analyses yield confidence intervals of different lengths. The reason is that univariate meta-analysis ignores the correlation between the meta-analysis effects, whereas multivariate meta-analysis does not. When this correlation is positive, the standard error of the relative effect tends to be smaller in multivariate than in univariate meta-analysis; when the correlation is negative (as can happen for mutually exclusive outcomes), standard errors derived from multivariate analyses tend to be larger than those derived from univariate analyses (Figure 6). These differences can lead to some quantitatively different conclusions as with topic 18, in which the much smaller bivariate model standard error leads to a significant difference in the relative odds ratio not seen in the univariate analysis, or topic 2, in which the odds ratio is larger for the second outcome in the univariate analysis, but larger for the first outcome in the multivariate one.

Figure 4 Relative summary odds ratios from univariate and bivariate meta-analyses in topics 1 through 43

Filled circles are results from bivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ̂_1_ and θ̂_2_: meta-analysis means for the first and second outcome, respectively.

Figure 4 plots the relative treatment effects (summary odds ratios) for univariate and bivariate meta-analyses in topics 1 through 43, using the normal approximation.

Figure 5 Treatment effects with univariate and trivariate meta-analysis in topics 44 and 45

Filled circles are results from trivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ̂_1_ through θ̂_3_: meta-analysis means for the first through third outcome.

Figure 5 plots the relative treatment efects (summary odds ratios) for univariate and trivariate meta-analyses in topics 44 and 45, using the normal approximation.

Figure 6 Ratio of standard errors for log relative odds ratios from multivariate and univariate meta-analysis and estimated correlation coefficient between means

Filled circles denote topics where the jointly meta-analyzed outcomes are mutually exclusive. Empty circles denote topics where outcomes have an is-subset-of relationship.

Figure 6 plots the ratio of standard errors for log relative odds ratios from univariate and multivariate meta-analysis, and the estimated correlation coefficient between means.

#### Comparison of Between-Study Variances With Univariate Versus Multivariate Analyses

Figure 7 shows estimates of between-study variances with univariate versus multivariate analyses. Between-study variance estimates were larger with multivariate analyses compared with univariate in 32 out of 45 examples for the first outcome, 36 out of 45 for the second outcome and for both examples for the third outcome (sign test p<0.10^−6^ that variances are larger with multivariate analyses across all three outcomes). The above is consistent with the observations of Riley et al. who conjecture that the difficulty in estimating the between-study correlation may result in slightly inflated estimates for between-study variance with multivariate versus univariate meta-analysis.12,48

Figure 7 Between-study variance estimates in univariate versus multivariate analyses (frequentist analyses)

Figure 7 compares the between-study variance estimates with inivariate versus multivariate meta-analysis. Between-study variance estimates were larger with multivariate analyses compared to univariate in 32 out of 45 examples for the first outcome, 36 out of 45 for the second outcome and for both examples for the third outcome (sign test p<0.10^-6 that variances are larger with multivariate analyses across all three outcomes).

#### Information Flow Across Outcomes in Multivariate Meta-Analysis

Riley et al. provide formulas for the point estimates of the means and the standard errors for random effects bivariate meta-analysis in a restricted iterative generalized least squares (RIGLS) framework.48 Upon inspection of the formulas it is evident that when the two outcomes are analyzed jointly, the point estimate of the first outcome depends on the study results for the second outcome if the following three conditions hold: (a) the within-study covariances ∑_k, 12_ are nonzero; (b) the within-study variances ∑_k, 11_ are not all equal (∑_k, 11_ ≠ ∑_11_); and (c) the within-study covariances ∑_k, 12_ are not all equal (∑_k_, _12_ ≠ ∑_12_). Similarly, the point estimate of the second outcome depends on the study results for the first outcome if a set of analogous conditions holds. (The only change is in condition (b), which becomes ∑_k, 22_ ≠ ∑_22_). The covariance matrices for the summary effects always depend on both outcomes. Riley et al. suggest that information flow will increase as the elements of the within-study covariance matrices become more dissimilar.

If information flows from the second outcome to the first outcome, the point estimates of the first outcome may be different under the univariate and multivariate meta-analysis. Reciprocally, if information flows from the first outcome to the second outcome, the point estimates of the second outcome may be different with univariate and multivariate meta-analysis. Figure 8 and Figure 9 examine the relationship between the absolute difference in the meta-analysis estimates with univariate and multivariate methods, and the standard deviation of the within-study variances and covariances across the 45 topics. Under the Riley hypothesis, one might expect that the absolute differences would increase with these standard deviations. However, all the correlations are very small so in this sample of 45 topics, we see no strong evidence of information flow.

Figure 8 Difference in the point estimate for the first outcome with univariate and multivariate meta-analysis versus the standard deviation of the elements of the within-study covariance matrices for all studies within a topic (topics 1 through 45)

Differences between univariate and multivariate point estimates for the first outcome suggest flow of information from the second outcome to the first outcome.

Figure 8 scatter plots the difference in the point estimate for the first outcome with univariate and multivariate meta-analysis versus the variability in the elements of the within-study covariance matrix, for topics 1 through 45. No significant association is observed (P-values for Spearman’s correlation are all 0.27 or larger [0.73, 0.86, and 0.89, respectively]).

Figure 9 Difference in the point estimate for the second outcome with univariate and multivariate meta-analysis versus the standard deviation of the elements of the within-study covariance matrices for all studies within a topic (topics 1 through 45)

Differences between univariate and multivariate point estimates for the second outcome suggest flow of information from the first outcome to the second outcome.

Figure 9 scatter plots the difference in the point estimate for the second outcome with univariate and multivariate meta-analysis versus the variability in the elements of the within-study covariance matrix, for topics 1 through 45 (P-values for Spearman’s correlation are all 0.27 or larger [0.82, 0.46, and 0.27, respectively]).

Finally, information can flow towards the first meta-analysis mean, when additional studies exist for the second outcome, and reciprocally. Figure 10 provides scatter plots of the absolute difference in the meta-analysis estimates with multivariate and univariate models and the number of studies reporting only the other outcome. Overall, the observed association is not beyond what is expected by chance.

Figure 10 Difference in the point estimates with univariate and multivariate meta-analysis versus the number of studies reporting the other outcome (topics 1 through 45)

Figure 10 scatter plots the difference in the point estimates with univariate and multivariate meta-analysis versus the number of studies reporting the other outcome, for topics 1 through 45. Overall, the observed association is not beyond what is expected by chance (P-values for Spearman's correlation are 0.12 and 0.17, respectively).

#### Estimation of the Between-Study Correlation Parameters

Between-study correlations were poorly estimated in almost all topics (Table 14). The point estimates are approximately +1 or −1; the respective variances (obtained by applying the delta method to the fitted multivariate meta-analysis model results) were very large, indicating a relatively flat likelihood with respect to the correlation parameter. In some sense, the fitted models provide very little information about the correlation. This observation is concordant with published analyses of single examples.11

Table 14 Estimated between-study correlation between the first and second outcome

Topic | ρ̂_12_ var(ρ̂_12_)
1 | 1.00 (-)
2 | 1.00 (-)
3 | 1.00 (-)
4 | −1.00 (-)
5 | −1.00 (-)
6 | 1.00 (-)
7 | 1.00 (-)
8 | 1.00 (-)
9 | −1.00 (-)
10 | −1.00 (0.04)
11 | 1.00 (-)
12 | 1.00 (-)
13 | 1.00 (-)
14 | 1.00 (-)
15 | 1.00 (-)
16 | 1.00 (-)
17 | 0.63 (0.10)
18 | −0.78 (-)
19 | 1.00 (-)
20 | 1.00 (-)
21 | −1.00 (-)
22 | 1.00 (-)
23 | −0.43 (2.59)
24 | 1.00 (-)
25 | 0.91 (0.13)
26 | 0.13 (0.95)
27 | 1.00 (-)
28 | 1.00 (-)
29 | 0.21 (-)
30 | 1.00 (-)
31 | 1.00 (-)
32 | −1.00 (-)
33 | 1.00 (-)
34 | 1.00 (-)
35 | 0.08 (-)
36 | 0.05 (-)
37 | 0.99 (-)
38 | −1.00 (-)
39 | −1.00 (-)
40 | 1.00 (-)
41 | −1.00 (-)
42 | 1.00 (-)
43 | −0.99 (-)
44 | −1.00 (-)
45 | 1.00 (-)

The dash (“-”) denotes an estimated variance larger than 1000. In the trivariate meta-analyses in topics 44 and 45, the estimated correlation coefficients (and variances) between the first and third outcome were −1 (42.2) and 0.98 (0.02), respectively; and between the second and third outcome they were 1 (>1000) and 0.97 (>1000).

Consequently, it is not surprising that the estimated means from the multivariate models differ little from their univariate counterparts. In general, one should not expect much information flow in three situations: 1) correlations are not well-estimated; 2) correlation is zero (because then the outcomes are independent); and 3) correlations are +1 or −1 (because then the outcomes are redundant).

### Meta-Analyses Using the Binomial or Multinomial Likelihood

Analyses with these models were performed in the Bayesian framework (see “Meta-Analysis Models Using the Discrete Likelihood,” above). Modeling within-study variation based on the binomial (for univariate meta-analyses) or the multinomial (for multivariate meta-analyses) distribution does not require continuity corrections or the use of a regularizer (a ridge regression correction). Overall, results were very similar to those obtained from models using the normal approximation. For example, Figure 11 and Figure 12 are the counterparts of Figure 2 and Figure 3, respectively. Similarly, Figure 13 and Figure 14 are the counterparts of Figure 4 and Figure 5, and Figure 15 is the counterpart of Figure 7. The numerical results are provided in the Appendix Tables 5 and 6.

Figure 11 Comparison of univariate and multivariate meta-analysis using the binomial or the multinomial distribution to model within-study variance (topics 1 through 43)

Filled circles are results from bivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ_1_ : meta-analysis posterior median for the first outcome; θ_2_ : meta-analysis posterior median for the second outcome. For topics 1 through 38 those experiencing the first outcome are a subset of those experiencing the second outcome. For topics 39 through 43, the two outcomes are mutually exclusive. Small “x” markers denote truncated credible intervals.

Figure 11 plots a comparison of univariate and bivariate meta-analysis, using the binomial or the multinomial distribution to model within-study variance, for topics 1 through 43. Overall, results were very similar to those obtained from models using the normal approximation.

Figure 12 Comparison of univariate and trivariate meta-analysis using the binomial or the multinomial distribution to model within-study variance (topics 44 and 45)

Filled circles are results from trivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ_1_ through θ_3_ : meta-analysis posterior median for the three outcomes. The three outcomes have an is-subset-of relationship.

Figure 12 plots a comparison of univariate and trivariate meta-analysis, using the binomial or the multinomial distribution to model within-study variance, for topics 44 through 45. Overall, results were very similar to those obtained from models using the normal approximation.

Figure 13 Relative summary odds ratios from univariate and bivariate meta-analyses using the binomial or the multinomial distribution to model within-study variance (topics 1 through 43)

Filled circles are results from bivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ_1_ and θ_2_ : meta-analysis posterior medians for the first and second outcome, respectively. For topics 1 through 38 those experiencing the first outcome are a subset of those experiencing the second outcome. For topics 39 through 43, the two outcomes are mutually exclusive. Small “x” markers denote truncated credible intervals.

Figure 13 plots the relative treatment effects (summary odds ratios) from univariate and bivariate meta-analyses using the binomial or the multinomial distribution to model within-study variance, for topics 1 through 43. Overall, results were very similar to those obtained from models using the normal approximation.

Figure 14 Relative summary odds ratios from univariate and trivariate meta-analyses using the binomial or the multinomial distribution to model within-study variance (topics 44 and 45)

Filled circles are results from trivariate meta-analyses. Empty circles are results from univariate meta-analyses. θ_1_ through θ_3_ : meta-analysis posterior median for the three outcomes. The three outcomes have an is-subset-of relationship.

Figure 14 plots the relative treatment effects (summary odds ratios) from univariate and trivariate meta-analyses using the binomial or the multinomial distribution to model within-study variance, for topics 44 through 45. Overall, results were very similar to those obtained from models using the normal approximation.

Figure 15 Between-study variance estimates in univariate versus multivariate analyses in Bayesian analyses

Figure 15 plots between-study variance estimates in univariate versus multivariate analyses in Bayesian analyses

The posterior distribution of the between-study correlation parameter(s) reflected the prior chosen. With the noninformative prior, the posterior medians were closer to zero with extremely wide credible intervals that almost covered the entire potential range from −1 to 1. The prior informative on the sign moved the posterior median toward that boundary and slightly tightened the credible interval, which still remained wide, however (Table 15). This is congruent with the findings in Table 14 for analyses using the normal approximation. The signs of the correlation coefficients from analyses using the normal approximation (frequentist analyses) and analyses using the discrete likelihood (Bayesian analyses, noninformative priors) generally agreed (κ = 0.42, P=0.001).

Table 15 Posterior median and 95% credible interval for between-study correlations with uninformative priors and priors informative on the correlation sign

Quantity or topic | Noninformative prior | Prior informative on the sign of the correlation
ρ _12_
1 | 0.42 (−0.82, 0.96) | 0.69 (−0.66, 0.98)
2 | 0.45 (−0.88, 0.98) | 0.82 (−0.58, 0.99)
3 | 0.29 (−0.91, 0.97) | 0.68 (−0.73, 0.98)
4 | 0.28 (−0.86, 0.96) | 0.64 (−0.75, 0.98)
5 | 0.08 (−0.93, 0.94) | 0.48 (−0.84, 0.98)
6 | 0.76 (−0.68, 0.99) | 0.90 (−0.26, 0.99)
7 | 0.19 (−0.92, 0.96) | 0.66 (−0.78, 0.99)
8 | 0.04 (−0.94, 0.94) | 0.57 (−0.80, 0.99)
9 | −0.03 (−0.95, 0.92) | 0.32 (−0.86, 0.96)
10 | 0.40 (−0.85, 0.97) | 0.77 (−0.70, 0.99)
11 | 0.91 (0.27, 0.99) | 0.94 (0.54, 0.99)
12 | 0.87 (−0.11, 0.99) | 0.92 (0.09, 0.99)
13 | 0.52 (−0.81, 0.98) | 0.80 (−0.57, 0.99)
14 | 0.66 (−0.80, 0.98) | 0.87 (−0.58, 0.99)
15 | 0.68 (−0.32, 0.98) | 0.84 (−0.02, 0.99)
16 | 0.90 (0.36, 0.99) | 0.93 (0.54, 0.99)
17 | 0.63 (−0.27, 0.93) | 0.74 (−0.03, 0.95)
18 | 0.24 (−0.91, 0.96) | 0.62 (−0.84, 0.98)
19 | 0.15 (−0.92, 0.95) | 0.61 (−0.79, 0.98)
20 | 0.77 (−0.29, 0.98) | 0.88 (0.12, 0.99)
21 | −0.20 (−0.95, 0.83) | 0.24 (−0.84, 0.96)
22 | 0.40 (−0.90, 0.97) | 0.79 (−0.67, 0.99)
23 | 0.15 (−0.91, 0.92) | 0.49 (−0.78, 0.97)
24 | 0.48 (−0.90, 0.98) | 0.84 (−0.53, 0.99)
25 | 0.52 (−0.87, 0.97) | 0.78 (−0.56, 0.99)
26 | 0.98 (0.93, 0.99) | 0.99 (0.95, 1.00)
27 | 0.91 (−0.47, 0.99) | 0.91 (−0.47, 0.99)
28 | 0.78 (−0.58, 0.98) | 0.89 (−0.02, 0.99)
29 | 0.43 (−0.92, 0.98) | 0.80 (−0.70, 0.99)
30 | 0.75 (−0.82, 0.98) | 0.88 (−0.18, 0.99)
31 | 0.55 (−0.81, 0.98) | 0.85 (−0.48, 0.99)
32 | 0.27 (−0.89, 0.97) | 0.64 (−0.75, 0.98)
33 | 0.71 (−0.62, 0.98) | 0.88 (−0.15, 0.99)
34 | −0.01 (−0.94, 0.89) | 0.43 (−0.79, 0.99)
35 | 0.19 (−0.96, 0.97) | 0.70 (−0.71, 0.99)
36 | 0.26 (−0.90, 0.96) | 0.68 (−0.72, 0.99)
37 | 0.29 (−0.90, 0.97) | 0.69 (−0.78, 0.99)
38 | 0.59 (−0.87, 0.98) | 0.89 (−0.35, 0.99)
39 | −0.80 (−0.98, 0.11) | Not run^*^
40 | 0.53 (−0.61, 0.97) | Not run^*^
41 | −0.60 (−0.98, 0.71) | Not run^*^
42 | 0.73 (−0.45, 0.98) | Not run^*^
43 | −0.20 (−0.96, 0.92) | Not run^*^
44 | 0.44 (−1.00, 1.00) | 0.81 (0.07, 1.00)
45 | 0.99 (0.42, 1.00) | 0.99 (0.18, 1.00)
ρ _13_
44 | 0.32 (−1.00, 1.00) | 0.80 (0.06, 1.00)
45 | 0.98 (0.17, 1.00) | 0.97 (−0.08, 1.00)
ρ _23_
44 | 0.16 (−0.96, 0.99) | 0.78 (0.16, 1.00)
45 | 0.99 (0.72, 1.00) | 0.99 (0.68, 1.00)

* Topics 39–43 correspond to mutually exclusive outcomes. We have no intuition on whether the between-study correlation among the two log odds ratios is expected to be positive or negative. Recall that although the proportions of people experiencing mutually exclusive outcomes are negatively correlated, the respective treatment effects can be positively or negatively correlated.

## Illustrative Simulation Analyses (Aim 3)

### Fidelity of Simulations and Code Integrity

The means and covariances of the simulated counts in the comparator arm and the true effects θ_k, 1_ and θ_k, 2_ matched the simulation parameters closely for all 648 scenarios for mutually exclusive outcomes and all 648 scenarios for outcomes with an is-subset-of relationship. Detailed inspection of graphs of the distribution of the above parameters in scenarios corresponding to combinations of highest and lowest values for parameters, as well as 15 additional randomly chosen scenarios were not suggestive of any systematic errors in programing and analysis.

### Exploration of Influential Simulation Parameters With Analysis of Variance (ANOVA)

We used ANOVA to identify influential simulation parameters for the MSE, bias and coverage probability under univariate and multivariate meta-analysis. ANOVA was used as a screening tool. We examined up to two-way interactions between the most influential parameters. Table 16 shows results for simulations of mutually exclusive outcomes. Note that these simulations and their conclusions are symmetric with respect to the two outcomes, in that findings for the second outcome are analogous to findings for the first outcome. Table 17 outlines corresponding explorations for the case of outcomes that have an is-subset-of relationship. Note that the patterns of important factors differ between the first and the second outcome.

Table 16 Influential simulation parameters for random effects bivariate meta-analysis of two mutually exclusive outcomes

ANOVA factors | SS for θ̂_1_×10^−3^ | | | SS for θ̂_2_×10^−3^
ANOVA factors
ANOVA factors | MSE | Coverage | Bias | MSE | Coverage | Bias
K | 8.5^*^ | 18.7^*^ | – | 8.5^*^ | 18.5^*^ | –
N | 34.1^*^ | 1.6^*^ | 1.5^*^ | 34.1^*^ | 2.2^*^ | 1.1^*^
θ _1_ | 0.2^*^ | – | – | – | – | –
θ _2_ | – | – | – | 0.2 | – | 1.4
K×N | 4.0^*^ | – | – | 4.0^*^ | – | –
K×θ_1_ | 6 | – | – | – | – | –
K×θ_2_ | – | – | – | – | – | –
N×θ_1_ | 0.1^*^ | – | 0.8 | – | – | –
N×θ_2_ | – | – | – | 0.1 | – | 1.2^*^
τ_1_^2^ | – | – | – | – | – | –
τ_2_^2^ | – | – | – | – | – | –
ρ | – | – | – | – | – | –

SS: sum of squares of factors in an ANOVA model. The dash stands for factors or interactions with p-values of 0.10 or larger. The asterisks denote factors or interactions with p-value less than 0.05.

Table 17 Influential simulation parameters for random effects bivariate meta-analysis of two outcomes with an is-subset-of relationship

ANOVA factors | SS for θ̂_1_×10^−3^ | | | SS for θ̂_2_×10^−3^
ANOVA factors
ANOVA factors | MSE | Coverage | Bias | MSE | Coverage | Bias
K | 8.2^*^ | 16.2^*^ | – | 3.6^*^ | 21.1^*^ | –
N | 32.7^*^ | 1.2 | 6.3^*^ | 15.4^*^ | – | –
θ _1_ | 0.2 | – | 9.6^*^ | – | – | –
θ _2_ | – | – | – | – | – | –
K×N | 3.8^*^ | – | – | 1.8^*^ | – | –
K×θ_1_ | – | – | – | – | – | –
K×θ_2_ | – | – | – | – | – | –
N×θ_1_ | 0.1^*^ | – | 4.9^*^ | – | – | –
N×θ_2_ | – | – | – | 0.07 | – | –
τ_1_^2^ | – | – | – | – | – | –
τ_2_^2^ | – | – | – | – | – | –
ρ | – | – | – | – | – | –

SS: sum of squares of factors in an ANOVA model. The dash stands for factors or interactions with p-values of 0.10 or larger. The asterisks denote factors or interactions with p-value less than 0.05.

#### Why Are the MSE, Bias and Coverage Dependent on θ_1_ or θ_2_?

Interestingly, the MSE, bias and coverage depend on θ_1_ or θ_2_. The reason may not be immediately obvious; if anything, one would expect MSE, bias and coverage to be independent of the true means.

However, recall that in the normal approximation model, the conditional sample covariance matrices (the within-study covariance matrices) are calculated as functions of the proportions of events, and are thus dependent on the true means. Therefore, a correlation between the means and the calculated covariance matrices exists. This situation is analogous to univariate meta-analysis, where for non-variance-stabilizing link functions such as the log() or the logit() functions, the study effects (log risk ratio or log odds ratio, respectively) are correlated with their variances. The multivariate meta-analysis methods that use the multinomial to model within-study variance do not have this shortcoming.

### MSE, Bias and Coverage for Bivariate Random Effects Meta-Analysis

Based on the explorative analyses in Table 16 and Table 17 we report the MSE, bias and coverage averaging over choices for between-study heterogeneity and between-study correlations in the true means. Table 18 shows these results for two mutually exclusive outcomes.

Table 18 MSE, coverage and bias for random effects bivariate meta-analysis (two mutually exclusive outcomes) averaging over τ_1_^2^ , τ_2_^2^ and ρ

K | N | exp(θ_1_) | exp(θ_2_) | MSE for θ̂_1_ (×10^−3^) | MSE for θ̂_2_ (×10^−3^) | Bias for θ̂_1_ (×10^−3^) | Bias for θ̂_2_ (×10^−3^) | Coverage (%) for θ̂_1_ | Coverage (%) for θ̂_2_
10 | 50 | 1 | 1 | 28 | 28 | −2 | 0 | 98.8 | 98.8
10 | 50 | 1 | 1.5 | 28 | 25 | 0 | −6 | 98.7 | 98.8
10 | 50 | 1.5 | 1 | 25 | 28 | −5 | −1 | 98.7 | 98.9
10 | 50 | 1.5 | 1.5 | 25 | 25 | −4 | −5 | 98.7 | 98.8
10 | 100 | 1 | 1 | 14 | 14 | 0 | −1 | 98.6 | 98.9
10 | 100 | 1 | 1.5 | 14 | 13 | 0 | −1 | 98.8 | 98.6
10 | 100 | 1.5 | 1 | 13 | 14 | −2 | −1 | 98.6 | 98.5
10 | 100 | 1.5 | 1.5 | 13 | 13 | −1 | −2 | 98.5 | 98.4
10 | 500 | 1 | 1 | 3 | 3 | 0 | 0 | 98.4 | 98.3
10 | 500 | 1 | 1.5 | 3 | 3 | 0 | −1 | 98.6 | 98.5
10 | 500 | 1.5 | 1 | 3 | 3 | 0 | 1 | 98.4 | 98.5
10 | 500 | 1.5 | 1.5 | 3 | 3 | 0 | 0 | 98.5 | 98.3
20 | 50 | 1 | 1 | 14 | 14 | 0 | 1 | 98.1 | 97.9
20 | 50 | 1 | 1.5 | 14 | 13 | −1 | −9 | 98.0 | 97.7
20 | 50 | 1.5 | 1 | 13 | 13 | −11 | 1 | 97.5 | 98.0
20 | 50 | 1.5 | 1.5 | 12 | 12 | −7 | −6 | 97.8 | 97.6
20 | 100 | 1 | 1 | 7 | 7 | 0 | −1 | 97.5 | 97.6
20 | 100 | 1 | 1.5 | 7 | 6 | 1 | −3 | 97.4 | 97.5
20 | 100 | 1.5 | 1 | 6 | 7 | −3 | 2 | 97.4 | 97.4
20 | 100 | 1.5 | 1.5 | 6 | 6 | −2 | −2 | 97.5 | 97.4
20 | 500 | 1 | 1 | 1 | 1 | 0 | 0 | 97.4 | 97.4
20 | 500 | 1 | 1.5 | 1 | 1 | 1 | −1 | 97.2 | 97.4
20 | 500 | 1.5 | 1 | 1 | 1 | 0 | 0 | 97.5 | 97.4
20 | 500 | 1.5 | 1.5 | 1 | 1 | −1 | 0 | 97.3 | 97.1

Table 19 shows the results for two outcomes having an is-subset-of relationship. Overall, the pattern of results is similar in the two tables. Note that the coverage is consistently above the desired 95 percent, which suggests that the t distribution with one degree of freedom is somewhat conservative for the scenarios examined here. Results for scenarios where half the studies reported both outcomes and half reported only the first outcomes were similar (not shown).

Table 19 MSE, coverage and bias for random effects bivariate meta-analysis (two outcomes that have an is-subset-of relationship) averaging over τ_1_^2^ , τ_2_^2^ and ρ

K | N | exp(θ_1_) | exp(θ_2_) | MSE for θ̂_1_ (×10^−3^) | MSE for θ̂_2_ (×10^−3^) | Bias for θ̂_1_ (×10^−3^) | Bias for θ̂_2_ (×10^−3^) | Coverage (%) for θ̂_1_ | Coverage (%) for θ̂_2_
10 | 50 | 1 | 1 | 27 | 18 | −2 | −1 | 98.9 | 98.7
10 | 50 | 1 | 1.5 | 28 | 17 | −1 | 1 | 98.7 | 98.6
10 | 50 | 1.5 | 1 | 25 | 18 | −15 | 2 | 98.7 | 98.5
10 | 50 | 1.5 | 1.5 | 25 | 17 | −11 | 2 | 98.7 | 98.6
10 | 100 | 1 | 1 | 14 | 9 | 0 | −1 | 98.7 | 98.5
10 | 100 | 1 | 1.5 | 14 | 9 | 0 | 2 | 98.8 | 98.5
10 | 100 | 1.5 | 1 | 13 | 9 | −7 | −1 | 98.5 | 98.6
10 | 100 | 1.5 | 1.5 | 13 | 9 | −5 | 1 | 98.6 | 98.5
10 | 500 | 1 | 1 | 3 | 2 | 0 | 0 | 98.4 | 98.5
10 | 500 | 1 | 1.5 | 3 | 2 | 0 | 0 | 98.5 | 98.5
10 | 500 | 1.5 | 1 | 3 | 2 | −2 | 0 | 98.5 | 98.5
10 | 500 | 1.5 | 1.5 | 3 | 2 | −1 | 0 | 98.4 | 98.5
20 | 50 | 1 | 1 | 13 | 9 | 0 | 1 | 98.0 | 97.5
20 | 50 | 1 | 1.5 | 13 | 9 | −2 | −1 | 98.1 | 97.3
20 | 50 | 1.5 | 1 | 12 | 9 | −23 | 0 | 97.3 | 97.4
20 | 50 | 1.5 | 1.5 | 12 | 9 | −15 | 2 | 97.8 | 97.3
20 | 100 | 1 | 1 | 7 | 4 | −1 | −1 | 97.9 | 97.6
20 | 100 | 1 | 1.5 | 7 | 4 | 1 | 1 | 97.7 | 97.4
20 | 100 | 1.5 | 1 | 6 | 4 | −10 | 1 | 97.4 | 97.4
20 | 100 | 1.5 | 1.5 | 6 | 4 | −6 | 0 | 97.6 | 97.4
20 | 500 | 1 | 1 | 1 | 1 | 0 | 0 | 97.3 | 97.5
20 | 500 | 1 | 1.5 | 1 | 1 | 0 | 0 | 97.3 | 97.3
20 | 500 | 1.5 | 1 | 1 | 1 | −2 | 0 | 97.5 | 97.2
20 | 500 | 1.5 | 1.5 | 1 | 1 | −2 | 0 | 97.6 | 97.5

Table 20 and Table 21 are the corresponding results for τ_1_^2^ , τ_2_^2^ and ρ averaging over the factors that were most influential in the ANOVA exploratory analyses (the number of studies K, the sample size per study N, and the true means in each outcome θ_1_ and θ_2_). Note that the MSE, bias and coverage do not vary very much within each column, as expected. The Appendix has the corresponding results for univariate meta-analyses.

Table 20 MSE, coverage and bias for random effects bivariate meta-analysis (two mutually exclusive outcomes) averaging over K, N, θ_1_ and θ_2_

τ_1_^2^ | τ_2_^2^ | ρ | MSE for θ̂_1_ (×10^−3^) | MSE for θ̂_2_ (×10^−3^) | Bias for θ̂_1_ (×10^−3^) | Bias for θ̂_2_ (×10^−3^) | Coverage (%) for θ̂_1_ | Coverage (%) for θ̂_2_
0 | 0 | −0.8 | 10.5 | 10.2 | −1.9 | 0.0 | 98.2 | 98.0
0 | 0 | −0.5 | 10.3 | 10.8 | −2.3 | −2.0 | 98.1 | 98.1
0 | 0 | −0.2 | 10.8 | 10.6 | −1.0 | −2.2 | 98.1 | 98.0
0 | 0.1 | −0.8 | 10.5 | 10.8 | −1.9 | −2.2 | 98.3 | 97.9
0 | 0.1 | −0.5 | 10.8 | 10.4 | −0.7 | −0.6 | 98.0 | 98.3
0 | 0.1 | −0.2 | 10.5 | 10.7 | −1.9 | −3.0 | 98.0 | 98.0
0 | 0.5 | −0.8 | 10.7 | 10.8 | −0.4 | −0.4 | 98.0 | 98.1
0 | 0.5 | −0.5 | 10.6 | 10.7 | −1.4 | −2.0 | 98.1 | 98.1
0 | 0.5 | −0.2 | 10.7 | 10.6 | −1.9 | −1.5 | 98.1 | 98.2
0.1 | 0 | −0.8 | 10.7 | 10.8 | −2.4 | −1.5 | 98.3 | 98.0
0.1 | 0 | −0.5 | 10.6 | 10.7 | −2.9 | −0.4 | 98.2 | 98.1
0.1 | 0 | −0.2 | 10.6 | 10.6 | −1.1 | −2.5 | 98.0 | 97.9
0.1 | 0.1 | −0.8 | 10.8 | 10.4 | −2.1 | −1.1 | 97.9 | 98.0
0.1 | 0.1 | −0.5 | 10.5 | 10.9 | −2.8 | −1.4 | 98.1 | 97.8
0.1 | 0.1 | −0.2 | 10.6 | 10.7 | 0.0 | −1.7 | 98.2 | 98.0
0.1 | 0.5 | −0.8 | 10.9 | 11.0 | −1.7 | −3.2 | 97.9 | 97.9
0.1 | 0.5 | −0.5 | 10.6 | 10.7 | −0.3 | −3.1 | 98.0 | 98.0
0.1 | 0.5 | −0.2 | 10.8 | 11.0 | −2.0 | −0.4 | 98.0 | 98.0
0.5 | 0 | −0.8 | 10.6 | 10.6 | −3.3 | −0.8 | 97.9 | 98.1
0.5 | 0 | −0.5 | 10.5 | 10.9 | −0.4 | −1.5 | 98.1 | 98.0
0.5 | 0 | −0.2 | 10.5 | 10.5 | −0.7 | −1.7 | 97.9 | 98.2
0.5 | 0.1 | −0.8 | 10.7 | 10.4 | 0.7 | −2.2 | 98.0 | 98.2
0.5 | 0.1 | −0.5 | 11.0 | 10.6 | −1.7 | −1.0 | 98.1 | 98.3
0.5 | 0.1 | −0.2 | 10.8 | 10.4 | −1.8 | −1.5 | 98.0 | 98.3
0.5 | 0.5 | −0.8 | 10.9 | 10.7 | −2.2 | −0.6 | 98.0 | 98.0
0.5 | 0.5 | −0.5 | 10.6 | 10.6 | −1.5 | 0.3 | 98.2 | 98.1
0.5 | 0.5 | −0.2 | 10.8 | 10.3 | −3.0 | −0.7 | 98.1 | 98.3

Table 21 MSE, coverage and bias for random effects bivariate meta-analysis (two outcomes that have an is-subset-of relationship) averaging over K, N, θ_1_ and θ_2_

τ_1_^2^ | τ_2_^2^ | ρ | MSE for θ̂_1_ (×10^−3^) | MSE for θ̂_2_ (×10^−3^) | Bias for θ̂_1_ (×10^−3^) | Bias for θ̂_2_ (×10^−3^) | Coverage (%) for θ̂_1_ | Coverage (%) for θ̂_2_
0 | 0 | −0.8 | 10.5 | 7.1 | −4.8 | −1.2 | 98.0 | 98.1
0 | 0 | −0.5 | 10.1 | 6.9 | −4.1 | 0.9 | 98.2 | 98.0
0 | 0 | −0.2 | 10.4 | 7.1 | −5.6 | 1.2 | 98.3 | 97.9
0 | 0.1 | −0.8 | 10.2 | 7.1 | −4.0 | −0.2 | 97.9 | 98.0
0 | 0.1 | −0.5 | 10.8 | 7.1 | −3.0 | 1.7 | 98.0 | 97.9
0 | 0.1 | −0.2 | 10.4 | 7.0 | −3.7 | 0.8 | 98.1 | 97.9
0 | 0.5 | −0.8 | 10.7 | 7.0 | −5.3 | −1.6 | 98.1 | 97.7
0 | 0.5 | −0.5 | 10.2 | 6.9 | −3.5 | 0.7 | 98.2 | 97.9
0 | 0.5 | −0.2 | 10.5 | 7.2 | −1.9 | 2.7 | 98.0 | 97.9
0.1 | 0 | −0.8 | 10.5 | 6.9 | −4.9 | −0.2 | 98.0 | 98.0
0.1 | 0 | −0.5 | 10.4 | 7.0 | −4.3 | 0.7 | 97.9 | 97.8
0.1 | 0 | −0.2 | 10.5 | 7.0 | −4.1 | 0.7 | 98.2 | 98.1
0.1 | 0.1 | −0.8 | 10.4 | 7.2 | −3.0 | 1.7 | 98.1 | 97.9
0.1 | 0.1 | −0.5 | 10.4 | 7.2 | −6.5 | −0.4 | 98.1 | 97.6
0.1 | 0.1 | −0.2 | 10.5 | 6.9 | −4.5 | −0.5 | 98.0 | 98.1
0.1 | 0.5 | −0.8 | 10.6 | 7.0 | −5.5 | −0.1 | 98.0 | 98.0
0.1 | 0.5 | −0.5 | 10.3 | 7.0 | −2.4 | 0.9 | 98.2 | 98.0
0.1 | 0.5 | −0.2 | 10.7 | 7.2 | −6.0 | −0.7 | 98.2 | 97.9
0.5 | 0 | −0.8 | 10.3 | 6.9 | −4.3 | 0.5 | 98.1 | 98.0
0.5 | 0 | −0.5 | 10.5 | 6.9 | −4.4 | 0.5 | 98.3 | 98.2
0.5 | 0 | −0.2 | 10.5 | 7.2 | −6.5 | −1.5 | 98.0 | 97.9
0.5 | 0.1 | −0.8 | 10.5 | 7.0 | −4.5 | −0.1 | 98.0 | 98.0
0.5 | 0.1 | −0.5 | 10.7 | 7.1 | −3.9 | 1.6 | 98.3 | 98.2
0.5 | 0.1 | −0.2 | 10.5 | 7.1 | −3.4 | 0.7 | 98.0 | 97.8
0.5 | 0.5 | −0.8 | 10.5 | 7.2 | −4.6 | 0.4 | 98.3 | 98.1
0.5 | 0.5 | −0.5 | 10.5 | 7.0 | −5.5 | 0.2 | 98.2 | 97.9
0.5 | 0.5 | −0.2 | 10.5 | 7.2 | −4.4 | 0.5 | 98.1 | 98.0

### Comparison Between Univariate and Multivariate Meta-Analysis in Simulations

#### Comparison of Point Estimates

The point estimates for summary log odds ratios were very similar under univariate and multivariate meta-analysis. This is true for mutually exclusive outcomes (Figure 16), for outcomes with an is-subset-of relationship (Figure 17), and for sensitivity analysis scenarios where half of the studies did not report results for the second outcome (not shown). This finding is congruent with the conclusions of the empirical analyses.

Figure 16 Summary odds ratios from univariate and bivariate meta-analysis across all simulations (mutually exclusive outcomes)

The axes correspond to odds ratios. The reference line is the line of equality.

Figure 16 plots the summary odds ratios from univariate and bivariate meta-analysis, across all simulations, for mutually exclusive outcomes. The point estimates for summary log odds ratios were very similar under univariate and multivariate meta-analysis.

Figure 17 Summary odds ratios from univariate and bivariate meta-analysis across all simulations (outcomes with an is-subset-of relationship)

The axes correspond to odds ratios. The reference line is the line of equality.

Figure 17 plots the summary odds ratios from univariate and bivariate meta-analysis, across all simulations, for outcomes with an is-subset-of relationship. The point estimates for summary log odds ratios were very similar under univariate and multivariate meta-analysis.

In Figure 16 the scatter of the simulation points is identical for the two outcomes. This is because for mutually exclusive outcomes simulation results and conclusions are exactly symmetric with respect to the two outcomes. By contrast, for outcomes with an is-subset-of relationship (Figure 17), the random scatter of the points is greater for the first outcome than for the second outcome. This is expected, as the number of those experiencing the second outcome within each simulated study arm is larger, resulting in lower sampling variance.

#### Comparison of Standard Errors for the Mean Effects

As shown in Figure 18 for mutually exclusive outcomes and Figure 19 for outcomes with an is-subset-of relationship, the standard errors of the meta-analysis means are not substantially different in univariate versus bivariate analyses. This is congruent with the empirical results.

Figure 18 Standard errors of summary odds ratios with univariate and bivariate meta-analysis across all simulations (mutually exclusive outcomes)

The reference line is the line of equality.

Figure 18 plots the standard errors of summary odds ratios from univariate and bivariate meta-analysis, across all simulations, for mutually exclusive outcomes. The standard errors of the meta-analysis means are not substantially different in univariate versus bivariate analyses

Figure 19 Standard errors of summary odds ratios from univariate and bivariate meta-analysis across all simulations (outcomes with an is-subset-of relationship)

The reference line is the line of equality.

Figure 19 plots the standard errors of summary odds ratios with univariate and bivariate meta-analysis, across all simulations, for outcomes with an is-subset-of relationship. The standard errors of the meta-analysis means are not substantially different in univariate versus bivariate analyses

Again, note that the two panels in Figure 18 are identical, because the simulation is symmetric with respect to the two mutually exclusive outcomes. In Figure 19, the standard errors for the second outcome are smaller than those for the first outcome; the explanation is the same as for Figure 17.

#### Comparison of Standard Errors of Differences in the Mean Effects

The most pronounced differences between univariate and bivariate meta-analyses pertain to the standard errors of differences in the summary estimates (or standard errors of linear combinations of the summary estimates in general5,11). In simulations of mutually exclusive outcomes, the between-study correlation is most often negative, and thus the standard error of the difference in the two means tends to be larger with bivariate compared with univariate meta-analysis (Figure 20). In simulations of outcomes that have an is-subset-of relationship the standard error with univariate meta-analyses tends to be larger than the standard error with multivariate meta-analyses (Figure 21), because the correlations between the outcomes were simulated to be positive, and are estimated as such. The patterns evident in the scatterplots correspond to combinations of simulation parameters, mainly study sample size N and the number of studies in a meta-analysis K.

Figure 20 Comparison of standard errors of the difference in the log summary odds ratios of two mutually exclusive outcomes with univariate and bivariate meta-analysis

The reference line is the line of equality.

Figure 20 plots a comparison of standard errors of the difference in the log summary odds ratios of two mutually exclusive outcomes with univariate and bivariate meta-analysis. The between-study correlation is most often negative, and thus the standard error of the difference in the two means tends to be larger with bivariate compared to univariate meta-analysis.

Figure 21 Comparison of standard errors of the difference in the log summary odds ratios of two outcomes that have an is-subset-of relationship with univariate and bivariate meta-analysis

The reference line is the line of equality.

Figure 21 plots a comparison of standard errors of the difference in the log summary odds ratios of two outcomes that have an is-subset-of relationship, with univariate and bivariate meta-analysis. The standard error with univariate meta-analyses tends to be larger than the standard error with multivariate meta-analyses.