# References

1 Jackson D, Riley R, White IR. Multivariate meta-analysis: Potential and promise. Stat Med. Jan. 26. 2011. [epub ahead of print].
2 Gleser LJ, Olkin I. Stochastically dependent effect sizes. Cooper H, Hedges LV, editors. The handbook of research synthesis. 2nd. New York. Russel Sage Foundation. 1994:339-55.
3 Van Houwelingen HC, Zwinderman KH, Stijnen T. A bivariate approach to meta-analysis. Stat Med. Dec. 30. 1993;12(24):2273-84. [pmid: 7907813].
4 van Houwelingen HC, Arends LR, Stijnen T. Advanced methods in meta-analysis: multivariate approach and meta-regression. Stat Med. 2002;21(4):589-624. [pmid: 11836738].
5 Trikalinos TA, Olkin I. A method for the meta-analysis of mutually exclusive binary outcomes. Stat Med. 2008;27(21):4279-300. [pmid: 18416445].
6 Arends LR. Multivariate meta-analysis: Modeling the heterogeneity (PhD Thesis). Haveka BV. Alblasserdam. 2006.
7 Berkey CS, Anderson JJ, Hoaglin DC. Multiple-outcome meta-analysis of clinical trials. Stat Med. 1996;15(5):537-57. [pmid: 8668877].
8 Berkey CS, Hoaglin DC, Antczak-Bouckoms A, et al. Meta-analysis of multiple outcomes by regression with random effects. Stat Med. 1998;17(22):2537-50. [pmid: 9839346].
9 Jackson D, White IR, Thompson SG. Extending DerSimonian and Laird’s methodology to perform multivariate random effects meta-analyses. Stat Med. May. 30. 2010;29(12):1282-97. [pmid: 19408255].
10 Mavridis D, Salanti G. A practical introduction to multivariate meta-analysis. Stat Methods Med Res. Feb. 16. 2012. [Epub ahead of print].
11 Trikalinos TA, Olkin I. Meta-analysis of effect sizes reported at multiple time points: a multivariate approach. Clin Trials. 2012;9(5):610-20. [pmid: 22872546].
12 Riley RD. Multivariate meta-analysis: the effect of ignoring within-study correlation. J Royal Stat Soc A. 2009;172(4):789-811.
13 Peter I, Crosier MD, Yoshida M, et al. Associations of APOE gene polymorphisms with bone mineral density and fracture risk: a meta-analysis. Osteoporosis Int. Apr. 2011;22(4):1199-209.
14 Hamza TH, van Houwelingen HC, Stijnen T. The binomial distribution of meta-analysis was preferred to model within-study variability. J Clin Epidemiol. Jan. 2008;61(1):41-51. [pmid: 18083461].
15 Stijnen T, Hamza TH, Ozdemir P. Random effects meta-analysis of event outcome in the framework of the generalized linear mixed model with applications in sparse data. Stat Med. Dec. 20. 2010;29(29):3046-3067. [pmid: 20827667].
16 White IR. Multivariate random effects meta-regression. Stata J. 2011;11:255-70.
17 Greenhalgh J, Hockenhull J, Rao N, et al. Drug-eluting stents versus bare metal stents for angina or acute coronary syndromes. Cochrane Database Syst Rev. 2010(5):CD004587. [pmid: 20464732].
18 Rostom A, Dube C, Wells G, et al. Prevention of NSAID-induced gastroduodenal ulcers. Cochrane Database Syst Rev. 2002(4):CD002296. [pmid: 12519573].
19 Halliday HL, Ehrenkranz RA, Doyle LW. Late (>7 days) postnatal corticosteroids for chronic lung disease in preterm infants. Cochrane Database Syst Rev. 2009(1):CD001145. [pmid: 19160189].
20 Barrington KJ, Finer N. Inhaled nitric oxide for respiratory failure in preterm infants. Cochrane Database Syst Rev. 2010(12):CD000509. [pmid: 21154346].
21 Gong Y, Huang ZB, Christensen E, et al. Ursodeoxycholic acid for primary biliary cirrhosis. Cochrane Database Syst Rev. 2008(3):CD000551. [pmid: 18677775].
22 Hodson EM, Willis NS, Craig JC. Corticosteroid therapy for nephrotic syndrome in children. Cochrane Database Syst Rev. 2007(4):CD001533. [pmid: 17943754].
23 Brion LP, Bell EF, Raghuveer TS. Vitamin E supplementation for prevention of morbidity and mortality in preterm infants. Cochrane Database Syst Rev. 2003(4):CD003665.
24 Brown J, O’Brien PM, Marjoribanks J, et al. Selective serotonin reuptake inhibitors for premenstrual syndrome. Cochrane Database Syst Rev. 2009(2):CD001396. [pmid: 19370564].
25 Al-Inany HG, Youssef MA, Aboulghar M, et al. Gonadotrophin-releasing hormone antagonists for assisted reproductive technology. Cochrane Database Syst Rev. 2011(5):CD001750. [pmid: 21563131].
26 Draper BH, Morroni C, Hoffman M, et al. Depot medroxyprogesterone versus norethisterone oenanthate for long-acting progestogenic contraception. Cochrane Database Syst Rev. 2006(3):CD005214. [pmid: 16856087].
27 Roberts D, Dalziel S. Antenatal corticosteroids for accelerating fetal lung maturation for women at risk of preterm birth. Cochrane Database Syst Rev. 2006(3):CD004454. [pmid: 16856047].
28 Renfrew MJ, McCormick FM, Wade A, et al. Support for healthy breastfeeding mothers with healthy term babies. Cochrane Database Syst Rev. 2012;5:CD001141. [pmid: 22592675].
29 Hofmeyr GJ, Xu H. Amnioinfusion for meconium-stained liquor in labour. Cochrane Database Syst Rev. 2010(1):CD000014. [pmid: 20091497].
30 Soares-Weiser K, Goldberg E, Tamimi G, et al. Rotavirus vaccine for preventing diarrhoea. Cochrane Database Syst Rev. 2004(1):CD002848. [pmid: 14973994].
31 Hodson EM, Craig JC, Strippoli GF, et al. Antiviral medications for preventing cytomegalovirus disease in solid organ transplant recipients. Cochrane Database Syst Rev. 2008(2):CD003774. [pmid: 18425894].
32 Wilhelmus KR. Antiviral treatment and other therapeutic interventions for herpes simplex virus epithelial keratitis. Cochrane Database Syst Rev. 2010(12):CD002898. [pmid: 21154352].
33 Webster AC, Ruster LP, McGee R, et al. Interleukin 2 receptor antagonists for kidney transplant recipients. Cochrane Database Syst Rev. 2010(1):CD003897. [pmid: 20091551].
34 Webster A, Woodroffe RC, Taylor RS, et al. Tacrolimus versus cyclosporin as primary immunosuppression for kidney transplant recipients. Cochrane Database Syst Rev. 2005(4):CD003961. [pmid: 16235347].
35 Schieppati A, Perna A, Zamora J, et al. Immunosuppressive treatment for idiopathic membranous nephropathy in adults with nephrotic syndrome. Cochrane Database Syst Rev. 2004(4):CD004293. [pmid: 15495098].
36 Furukawa T, McGuire H, Barbui C. Low dosage tricyclic antidepressants for depression. Cochrane Database Syst Rev. 2003(3):CD003197. [pmid: 12917952].
37 Carlisle JB, Stevenson CA. Drugs for preventing postoperative nausea and vomiting. Cochrane Database Syst Rev. 2006(3):CD004125. [pmid: 16856030].
38 Bell RF, Dahl JB, Moore RA, et al. Perioperative ketamine for acute postoperative pain. Cochrane Database Syst Rev. 2006(1):CD004603. [pmid: 16437490].
39 Stacey D, Bennett CL, Barry MJ, et al. Decision aids for people facing health treatment or screening decisions. Cochrane Database Syst Rev. 2011(10):CD001431. [pmid: 21975733].
40 Oates-Whitehead RM, Baumer JH, Haines L, et al. Intravenous immunoglobulin for the treatment of Kawasaki disease in children. Cochrane Database Syst Rev. 2003(4):CD004000. [pmid: 14584002].
41 Hodnett ED, Gates S, Hofmeyr GJ, et al. Continuous support for women during childbirth. Cochrane Database Syst Rev. 2011(2):CD003766. [pmid: 21328263].
42 Duley L, Henderson-Smart DJ, Meher S, et al. Antiplatelet agents for preventing pre-eclampsia and its complications. Cochrane Database Syst Rev. 2007(2):CD004659. [pmid: 17443552].
43 Hatem M, Sandall J, Devane D, et al. Midwife-led versus other models of care for childbearing women. Cochrane Database Syst Rev. 2008(4):CD004667. [pmid: 18843666].
44 Furukawa TA, Streiner DL, Young LT. Antidepressant and benzodiazepine for major depression. Cochrane Database Syst Rev. 2002(1):CD001026. [pmid: 11869584].
45 Amsallem E, Kasparian C, Haddour G, et al. Phosphodiesterase III inhibitors for heart failure. Cochrane Database Syst Rev. 2005(1):CD002230. [pmid: 15674893].
46 Valgimigli M, Campo G, Arcozzi C, et al. Two-year clinical follow-up after sirolimus-eluting versus bare-metal stent implantation assisted by systematic glycoprotein IIb/IIIa Inhibitor Infusion in patients with myocardial infarction: results from the STRATEGY study. J Am Coll Cardiol. Jul. 10. 2007;50(2):138-45. [pmid: 17616297].
47 Valgimigli M, Percoco G, Malagutti P, et al. Tirofiban and sirolimus-eluting stent vs abciximab and bare-metal stent for acute myocardial infarction: a randomized trial. JAMA. May. 4. 2005;293(17):2109-17. [pmid: 15870414].
48 Riley RD, Abrams KR, Lambert PC, et al. An evaluation of bivariate random-effects meta-analysis for the joint synthesis of two correlated outcomes. Stat Med. Jan. 15. 2007;26(1):78-97. [pmid: 16526010].
49 Riley RD, Abrams KR, Sutton AJ, et al. Bivariate random-effects meta-analysis and the estimation of between-study correlation. BMC Med Res.Methodol. 2007;7:3. [pmid: 17222330].
50 Trikalinos TA, Hoaglin DC, Small KM, et al. Methods for the joint meta-analysis of multiple tests. Rockville, MD. Agency for Healthcare Research and Quality. 2013.
51 Kirkham JJ, Riley RD, Williamson PR. A multivariate meta-analysis approach for reducing the impact of outcome reporting bias in systematic reviews. Stat Med. Sep. 10. 2012;31(20):2179-95. [pmid: 22532016].