# Methods

Having information on the correlations between the outcomes observed in each study (i.e., within-study correlations) is necessary for the joint meta-analysis of two or more outcomes, unless one is prepared to make assumptions such as that the within and between-study correlations are related.12

For some problems, such information is not extractable from data reported in published studies, and one has to obtain individual patient data (for example, see Peter et al.13) or to impute the missing information based on prior knowledge, as was done in the example in Berkey et al.8 (This is true for all joint meta-analyses of continuous outcomes and for many joint meta-analyses between categorical outcomes.) For other problems (all of which pertain to categorical outcomes) the numbers in the cross-classification of outcomes are exactly recoverable. Thus, one can calculate within-study correlations (or equivalent information) from typically reported data. These are cases where:

1. The outcomes are mutually exclusive, that is, a person can experience only one of them. Examples are the pair of outcomes “death from breast cancer” and “death from causes other than breast cancer” and the pair “births by caesarean section” and “spontaneous vaginal births.”5
2. The people experiencing one outcome are a subset of the people experiencing the other outcome. Such is the pair of outcomes “survival at 6 months” and “survival at 12 months,” because those alive at 12 months are a subset of those who were alive at 6 months. Similarly, “withdrawals due to adverse events” are a subset of “withdrawals for any reason.”11

Table 1 shows an example of mutually exclusive outcomes, and Table 2 an example of outcomes that have an is-subset-of relationship. The examples extend to more than two outcomes in the obvious way.

Table 1 Observed counts for two mutually exclusive outcomes (study k )

Arm | Outcome 1: Breast cancer deaths | Outcome 2: Death from other causes | Alive (remaining) | Total
Comparator (C) | X_k_ _1_ | X_k_ _2_ | X_k_ _3_ | N_k_^( C )^ = X_k 1_ + X_k 2_ + X_k 3_
Treatment (T) | Y_k_ _1_ | Y_k_ _2_ | Y_k_ _3_ | N_k_^( T )^ = Y_k 1_ + Y_k 2_ + Y_k 3_

Table 2 Observed counts for two outcomes having an is-subset-of relationship (study k )

Arm | Outcome 1: Alive at 12 months | Outcome 2: Alive at 6 months | Total
Comparator (C) | A_k_ _1_ | A_k2_(≥ A_k1_) | N_k_^( C )^
Treatment (T) | B_k_ _1_ | B_k2_(≥ B_k1_) | N_k_^( T )^

The outcomes “alive at 12 months” and “alive at 6 months” imply the following three mutually exclusive categories: “alive at 12 months,” “dying between 6 and 12 months,” and “dying between 0 and 6 months.” Denote the counts for the latter three categories in the comparator by F_k1_, F_k2_, and F_k3_ and in the treatment by G_k1_, G_k2_, and G_k3_ respectively. Then F_k1_ = A_k1_, F_k1_ + F_k2_ = A_k2_, and F_k1_ + F_k2_ + F_k3_ = N^(C)^_k_, and analogously for the treatment arm.

## Aim 1 Formation of the Database

### Eligibility Criteria

A single investigator (TT) screened the Cochrane Database of Systematic Reviews, Quarter 1, 2012, to identify pairs or triplets of univariate meta-analyses for which numbers on cross-classification of outcomes are exactly recoverable, and that can be meta-analyzed jointly. Eligible were pairs or triplets of univariate meta-analyses

1. with categorical outcomes;
2. comparing the same interventions;
3. having at least seven randomized controlled trials, RCTs,^a^ (or at least half of the RCTs if the number of studies K>14) with at least two events and at least 10 patients per arm;
  a Although the vast majority of studies in Cochrane reviews are randomized, a few are not. Nevertheless, we refer to all studies in Cochrane meta-analyses as “RCTs.”
4. where an adequate number of RCTs reported all outcomes of interest.^b^ This was defined as at least seven RCTs with two or more events per arm (or at least half of the RCTs if K>14); and
  b Paragraph “On the Number of Parameters to be Estimated” in the Model Fitting subsection below explains the rationale for choosing K=7 as the minimum number of studies in a meta-analysis.
5. reporting actual data rather than sensitivity analyses (such as “worst case scenario” analyses).

We excluded Cochrane reviews that have been withdrawn. We did not consider collections of studies that have not been pooled quantitatively by the primary Cochrane reviewers (irrespective of rationale). When the primary Cochrane reviewers performed quantitative syntheses within subgroups of studies but not across these subgroups, we considered each subgroup as a distinct univariate meta-analysis. When the primary reviewers pooled across subgroups, we ignored subgroup classifications and considered the overall synthesis as a single meta-analysis. We excluded meta-analyses of survival outcomes based on approximating a log hazard ratio using the numbers of observed minus expected events.

Some Cochrane reviews could contribute more than one otherwise eligible pair or triplet of outcomes. When applicable, we preferred to form triplets of meta-analyses to selecting one of the three possible pairs in a triplet. To avoid duplication of information, we included only independent pairs or triplets of univariate meta-analyses from a single Cochrane review. These were defined as pairs or triplets pertaining to different intervention comparisons, or pairs or triplets that included nonoverlapping collections of RCTs.

Among nonindependent pairs or triplets of outcomes, we selected the one with the largest number of RCTs reporting all outcomes. We broke any ties by selecting the pair or triplet of meta-analyses with the largest total number of randomized patients, then the largest total number of events, and then randomly.

### Screening

We electronically identified all pairs or triplets of meta-analyses with at least seven studies in common. From this set, we manually examined the descriptions of the outcomes and interventions and selected the final candidates based on the full text of the Cochrane review.

### Data Extraction

For each eligible pair or triplet of univariate meta-analyses, we recorded the title and identification code of the parent Cochrane review, the compared interventions, outcomes, subgroup definitions (if applicable), the Cochrane Library identification numbers of the included RCTs, and the first author and the year of publication of each RCT. We also recorded the number of events for each outcome and each arm. Finally, we categorized the topics of eligible reviews as pertinent to general medicine, pediatrics, obstetrics and gynecology, nephrology, mental health, cardiology, infectious diseases, and surgery.

## Aim 2 Comparison Between Univariate and Multivariate Meta-Analysis

For each eligible pair or triplet of meta-analyses of outcomes we performed univariate (separate) and multivariate (joint) meta-analyses with both fixed and random effects. We used two modeling approaches: the first modeled within-study variability with normal distributions, and the second used discrete distributions (binomial for univariate meta-analysis, multinomial for multivariate). Because most meta-analyses involve clinical and methodological heterogenity, we report results from random effects analyses in the main text of the report. We report results from fixed effects analyses in the Appendix.

### Meta-Analysis Models

Assume that we have K studies (indexed by k) reporting M outcomes (indexed by m). The individual outcomes are either mutually exclusive and associated with a single period of follow-up, or have an is-subset-of relationship. Continuing with the example in Table 1, Table 3 shows the true (population) probabilities for the categories defined by outcomes that are mutually exclusive.

Table 3 True probabilities for experiencing two mutually exclusive outcomes (study k)

Arm | Outcome 1: Breast cancer deaths | Outcome 2: Death from other causes | Alive (remaining)
Comparator (C) | π_k 1_^( C )^ | π_k 2_^( C )^ | π_k 3_^( C )^ = 1 - π_k 1_^( C )^ - π_k 2_^( C )^
Treatment (T) | π_k 1_^( T )^ | π_k 2_^( T )^ | π_k 3_^( T )^ = 1 - π_k 1_^( T )^ - π_k 2_^( T )^

This table corresponds to Table 1 (observed counts).

Sets of outcomes that have an is-subset-of relationship imply a set of mutually exclusive categories (Table 4). The true probabilities for experiencing outcomes that have an is-subset-of relationship are summations over the cells of Table 4, as defined in Table 5. One can extend the notation to more than two outcomes in the obvious way.

Table 4 True probabilities for the mutually exclusive categories implied by two outcomes that have an is-subset-of relationship (study k)

Arm | Alive at 12 months | Dying between 6 and 12 months | Dying between 0 and 6 months
Comparator (C) | γ_k 1_^( C )^ | γ_k 2_^( C )^ | γ_k 3_^( C )^ = 1 - γ_k 1_^( C )^ - γ_k 2_^( C )^
Treatment (T) | γ_k 1_^( T )^ | γ_k 2_^( T )^ | γ_k 3_^( T )^ = 1 - γ_k 1_^( T )^ - γ_k 2_^( T )^

Table 5 True probabilities for two outcomes that have an is-subset-of relationship (study k) as a function of the mutually exclusive quantities in Table 4

Arm | Outcome 1: Alive at 12 months | Outcome 2: Alive at 6 months
Comparator (C) | λ_k 1_^( C )^ = γ_k 1_^( C )^ | λ_k 2_^( C )^ = γ_k 1_^( C )^ + γ_k 2_^( C )^
Treatment (T) | λ_k 1_^( T )^ = γ_k 1_^( T )^ | λ_k 2_^( T )^ = γ_k 1_^( T )^ + γ_k 2_^( T )^

The γ’s are mutually exclusive and exhaustive within each treatment arm (Table 4), but the λ’s are not. This table corresponds to Table 2 (observed counts).

#### Univariate Meta-Analysis

##### Structural Model

Equal Effects (“Fixed Effects”). For mutually exclusive outcomes, the true effect size for outcome m (here, the log odds ratio, log OR) in study k is

θ_k m_ = logit ( γ_k m_^( T )^ ) - logit ( γ_k m_^( C )^ ) 1

For outcomes that have an is-subset-of relationship, write

θ_k m_ = logit ( λ_k m_^( T )^ ) - logit ( λ_k m_^( C )^ ) 2

Under a fixed effects meta-analysis model, the true effect for each outcome is the same in all K studies

θ_km_ = θ_m_. 3

Random-Effects. For random effects we assume that the true effect in each study is normally distributed around a mean θ_m_ with a between-study variance τ_m_^2^ . Thus (3) is replaced by

θ_k m_ ~ N ( θ_m_ , τ_m_^2^ ) . 4

All other model-defining equations remain the same.

##### Observational Model

One has two options in modeling within-study variation. The first option is to assume that the sample estimate of the log odds ratio, θ̂_m_, is normally distributed

θ^_k m_ ~ N ( θ_k m_ , σ_k m_^2^ ) , 5

with the sample conditional variance σ_k m_^2^ assumed known and calculated from the data. (This assumption is often made in meta-analysis, but without formal justification.) For mutually exclusive outcomes

θ^_k m_ = logit ( (Y_k m_)/(N_k_^( T )^) ) - logit ( (X_k m_)/(N_k_^( C )^) ) , and 6

σ_k m_^2^ = (1)/(Y_k m_) + (1)/(N_k_^( T )^ - Y_k m_) + (1)/(X_k m_) + (1)/(N_k_^( C )^ - X_k m_) . 7

For outcomes with an is-subset-of relationship, substitute A_km_ for X_km_ and B_km_ for Y_km_ in (6) and (7).

Alternatively, one can model the number of events in Table 1 and Table 2 with binomial distributions. For the case of mutually exclusive outcomes

X_k m_ ~ B ( N_k_^( C )^ , π_k m_^( C )^ ) , and 8

Y_k m_ ~ B ( N_k_^( T )^ , π_k m_^( T )^ ) . 9

For outcomes with an is-subset-of relationship

A_k m_ ~ B ( N_k_^( C )^ , λ_k m_^( C )^ ) , and 10

B_k m_ ~ B ( N_k_^( T )^ , λ_k m_^( T )^ ) . 11

#### Multivariate Meta-Analysis

We are interested in the same comparisons as in the univariate case. As explained elsewhere, outcomes that are mutually exclusive or have an is-subset-of relationship are correlated and can be analyzed jointly.5,11 The key is to capitalize on the multinomial structure of the data, which is outlined in Table 3 and in Table 4, respectively.

##### Structural Model

Equal Effects (“Fixed Effects”). Arrange the M true effects in study k in a column vector Θ_k_ = (θ_k1_,..., θ_kM_)′, with prime (′) denoting transpose and boldface denoting vectors (or matrices). The elements θ_km_ are defined by (1) for mutually exclusive outcomes and (2) for outcomes with an is-subset-of relationship. Under fixed effects, the true effects in all K studies are the same:

Θ_k_ = Θ. 12

Random-Effects. In the random effects case, in place of (12) the vector of the true treatment effects Θ_k_ is assumed to follow a multivariate normal distribution

Θ_k_ ~ N (Θ, T), 13

where T is an M × M between-study covariance matrix. Trikalinos and Olkin discuss parameterizations for T.5,11 In this work we use an unstructured T = (τ_ij_).

##### Observational Model

Write Θ̂_k_ = (θ̂_k1_,..., θ̂_kM_)′ for the estimate of Θ_k_. In analogy to the univariate meta-analysis case, one can model within-study variability with a multivariate normal distribution

Θ̂_k_ ~ N (Θ_k_, ∑_k_), 14

where ∑_k_ is an M × M covariance matrix encoding the correlations between the outcomes within each study. The elements of ∑_k_ are assumed known and are calculated from the data using the formulas in the Appendix. (As noted in the univariate case, this assumption is not always formally justified.) For details on formulas see the appendices in the papers by Trikalinos and Olkin.5,11 Note that the formulas for the covariances are different for outcomes that are mutually exclusive compared with outcomes that have an is-subset-of relationship. The analogy between (3) and (12) and between (5) and (14) is obvious.

Alternatively, one can use the multinomial distribution to model observed counts in each arm. For mutually exclusive outcomes, we write using the notation in Table 1 and Table 3:

( X_k 1_ , … , X_k M_ ) ~ M ( N_k_^( C )^ , ( π^( C )^_k 1_ , … , π^( C )^_k M_ ) ) 15

for the comparator arm, and

( Y_k 1_ , … , Y_k M_ ) ~ M ( N_k_^( T )^ , ( π^( T )^_k 1_ , … , π^( T )^_k M_ ) ) 16

for the treatment arm. For outcomes that have an is-subset-of relationship, we have to model the counts for the mutually exclusive categories implied by the outcomes of interest. As an example, the outcomes “alive at 6 months” and “alive at 12 months” imply the following three mutually exclusive categories: “alive at 12 months,” “dying between 6 and 12 months,” and “dying between 0 and 6 months.” Using the notation in Table 2 and Table 4, we write for the comparator and treatment arms

( F_k 1_ , F_k 2_ , F_k 3_ ) = ( A_k 1_ , A_k 2_ - A_k 1_ , N_k_^( C )^ - A_k 2_ ) ~ M ( N_k_^( C )^ , ( γ_k 1_^( C )^ , γ_k 2_^( C )^ , γ_k 3_^( C )^ ) ) , and 17

( G_k 1_ , G_k 2_ , G_k 3_ ) = ( B_k 1_ , B_k 2_ - B_k 1_ , N_k_^( T )^ - B_k 2_ ) ~ M ( N_k_^( T )^ , ( γ_k 1_^( T )^ , γ_k 2_^( T )^ , γ_k 3_^( T )^ ) ) , 18

respectively. It is easy to extend (17) and (18) to more than two outcomes with an is-subset-of relationship.

The discrete likelihood methods have several advantages and should be preferred providing software is available to carry them out.14,15 First, they model the exact probabilistic structure of the data, rather than using large sample approximation as for the normal likelihoods. Second, they require no knowledge of within-study correlation matrices, which may be poorly estimated. Third, they may be estimated without needing to resort to corrections for zero counts where the empirical logits are undefined.

#### Meta-Analysis Incorporating Missing Outcomes

In many cases, some studies report only a subset of outcomes. Assuming the unreported outcomes are missing at random, the study’s contribution to the likelihood can be written in terms of its M_k_ observed outcomes Θ̂_k_ = (θ̂_k1_,..., θ̂_kM_k__)′.

### Model Fitting

#### Meta-Analysis Models Using Normal Approximations

Univariate and multivariate meta-analyses using the normal distribution to model within-study variability were fitted with maximum likelihood for fixed effects, and restricted maximum likelihood for random effects. For details see Trikalinos and Olkin.5,11 For studies with singular covariance matrices (i.e., when the within-study correlation is +1 or -1) we used the ridge regression approach outlined in the appendix of Trikalinos and Olkin.11 The ridge regression is a form of regularized regression (details in the Appendix). In sensitivity analyses we excluded studies with singular covariance matrices; the results were very similar or identical to those from the ridge regression analyses, and are not shown.

#### Meta-Analysis Models Using the Discrete Likelihood

Univariate meta-analyses that use the binomial distribution to model counts in each study arm can be fit in the generalized linear mixed models framework using routines readily available in general statistical packages such as xtmelogit in Stata or lmer in R. However, the multivariate versions of the meta-analysis models specified here cannot be fit in these general routines. The available generalized linear mixed model (GLMM) packages in R, Stata and SAS do not allow the user to specify the random effects distribution in (13), where the random effects pertain to the log ORs. Instead they only allow specification of models in which the random effects are on the logit-transformed probabilities in Table 3 or Table 4.

Optimizing the likelihood for the random effects multinomial model outside a GLMM package is nontrivial, because it involves calculating complicated integrals numerically. Thus we did not develop routines for fitting this model. Instead we fitted the model using Markov Chain Monte Carlo (MCMC) methods in the Bayesian framework. For the Bayesian analyses we used vague (noninformative) prior distributions, as described in the Appendix, as well as prior distributions that were informative on the sign of the between-study correlation coefficients.

#### On the Number of Parameters to be Estimated

For each univariate meta-analysis the parameters to be estimated are the true mean θ_m_ for fixed effects, and the true mean and the between-study variance τ_m_^2^ for random effects. For multivariate meta-analyses, the parameters to be estimated are the M true means (the elements of Θ) for fixed effects, and the M(M + 1)/2 elements of the unstructured between-study covariance matrix T. To fit the models, we must have more independent data points than parameters. From each study k reporting all outcomes of interest we have M − 1 data points. So for random effects models, we must have (M − 1)K > M + M (M + 1) / 2, or K > M / (M − 1) + / M (M + 1) / (2(M − 1)). For example, for M = 2, K > 5. The minimum K is probably not sufficient, and thus we opted to set as an eligibility criterion for this project that meta-analyses should have at least seven studies reporting on all outcomes.

#### Software

(Restricted) maximum likelihood meta-analyses were performed in Stata using custom code (see the code in Trikalinos and Olkin 2012).11 Similar analyses can be performed using routines such as mvmeta in Stata.16 Bayesian meta-analyses were performed in JAGS (specifically, using the rjags library in R). We used three MCMC chains and a burn-in between 10000 and 50000 iterations. We monitored convergence with the Gelman-Rubin diagnostic for stochastic nodes corresponding to the meta-analysis means and the elements of their between-study covariance matrices. We declared convergence when the 97.5 percentile of the diagnostic was 1.10 or less for all monitored stochastic nodes, provided that on visual inspection the traceplots of the MCMC chains were suggestive of good mixing.

### Recorded Results

From each analysis, we recorded the summary effects for each outcome along with the respective variances (and covariances, if applicable), and results on between-study variances (covariances and correlations, as applicable). We also calculated pairwise differences between outcome effects, and the confidence intervals for these differences. These differences are the log relative odds ratios for observing one outcome versus the other, and are not necessarily helpful or informative for all contexts or topics; however, we calculated them for all topics, because this work makes technical rather than clinical conclusions and observations. We used the t distribution with K-1 degrees of freedom to construct confidence intervals for estimated means and differences of estimated means.

For Bayesian analyses we recorded the median and the 0.025 and 0.975 quantiles of the posterior distribution for each quantity of interest. The latter two can be thought as being the endpoints of a 95% credible interval (95% CrI), the Bayesian analogue of a 95% confidence interval.

## Aim 3 Simulation Analysis

We generated illustrative simulation data as described in the next two paragraphs.

### Simulation Parameters

Table 6 shows the simulation parameters. These span a representative range of scenarios. Zero between-study standard deviations correspond to fixed-effects realities, and are probably not the norm in real-life applications. However, they are examined for completeness.

Table 6 Simulation parameters

# | Parameter | Values
1 | Number of studies per meta-analysis, K_j_ | 10, 20
2 | Number of patients per study arm, N_j , k_^( T )^ = N_j , k_^( C )^ = N_j_ | 50, 100, 500 [Same for all k, and for both study arms]
3 | Vector of probabilities for the 3 categorical outcomes in the controls:; - For mutually exclusive outcomes: π_j , k_^( C )^ = π_j_^( C )^ , or ( π_j , k 1_^( C )^ , π_j , k 2_^( C )^ , π_j , k 3_^( C )^ ) = ( π_j , 1_^( C )^ , π_j , 2_^( C )^ , π_j , 3_^( C )^ ); - For outcomes with an is-subset-of relationship: γ_j , k_^( C )^ = γ_j_^( C )^ , or ( γ_j , k 1_^( C )^ , γ_j , k 2_^( C )^ , γ_j , k 3_^( C )^ ) = ( γ_j , 1_^( C )^ , γ_j , 2_^( C )^ , γ_j , 3_^( C )^ ) | (1/6, 1/6, 2/3) [Same for all k ]
4 | Marginal mean odds ratio for the first outcome, θ_j_,_1_ | 1, 1.5
5 | Marginal mean odds ratio for the second outcome, θ_j_,_2_ | 1, 1.5
6 | Between-study standard deviation for the log odds ratio of the first outcome, τ_j_,_1_ | 0, 0.1, 0.5
7 | Between-study standard deviation for the log odds ratio of the second outcome, τ_j_,_2_ | 0, 0.1, 0.5
8 | Between-study correlation between log-odds ratios for the two outcomes, ρ_j_ | 0.25, 0.50, 0.75

j indexes simulation scenarios. Write θ_j_ = (θ_j,1_, θ_j,2_)′, τ_j_ = (τ_j,1_, τ_j,2_)′, and R_j_ = [ 1 ρ_j_ 1 ] .

### Generation of Random Data

For each scenario we generated 500 random sets of studies on two correlated binary outcomes. The following pseudo-algorithms in Table 7 (for mutually exclusive outcomes) and Table 8 (for outcomes that have an is-subset-of relationship) explain the generation of simulation data for scenario j.

Table 7 Pseudo-algorithm for generating simulation data for mutually exclusive outcomes

Choose a combination of values for the parameters in Table 6.
Do 500 times (for notational simplicity we drop the index for the simulation draw):
Draw K vectors of counts for the three categories of events in the comparator arms:; X_j , k_ = ( X_j , k 1_ , X_j , k 2_ , X_j , k 3_ ) ~ M ( N_j_^( C )^ , ( π_j , k 1_^( C )^ , π_j , k 2_^( C )^ , π_j , k 3_^( C )^ ) )
Draw K vectors of study effects for outcomes 1 and 2 θ_j,k_ = (θ_j,k1_, θ_j,k2_)′ ~ N (θ, T), where T = diag(τ) R diag (τ)
Calculate the probabilities for the three categories of events in the treatment arms:; π_j , k 1_^( T )^ = logit^- 1^ ( θ_j , k 1_ + logit ( π_j , k 1_^( C )^ ) ) , π_j , k 2_^( T )^ = logit^- 1^ ( θ_j , k 2_ + logit ( π_j , k 2_^( C )^ ) ) , and π_j , k 3_^( T )^ = 1 - π_j , k 1_^( T )^ - π_j , k 2_^( T )^ .; If π_j , k 3_^( T )^ ≤ 0 , set; π_j , k 3_^( T )^ : = (10^- 4^)/(π_j , k 1_^( T )^ + π_j , k 2_^( T )^ + 10^- 4^) , π_j , k 2_^( T )^ : = (π_j , k 2_^( T )^)/(π_j , k 1_^( T )^ + π_j , k 2_^( T )^ + 10^- 4^) , and π_j , k 1_^( T )^ : = (π_j , k 1_^( T )^)/(π_j , k 1_^( T )^ + π_j , k 2_^( T )^ + 10^- 4^) .; Draw K vectors of counts for the three categories of events in the treatment arms:; Y_j , k_ = ( Y_j , k 1_ , Y_j , k 2_ , Y_j , k 3_ ) ~ M ( N_j_^( T )^ , ( π_j , k 1_^( T )^ , π_j , k 2_^( T )^ , π_j , k 3_^( T )^ ) )

Table 8 Pseudo-algorithm for generating simulation data for outcomes that have an is-subset-of relationship

Choose a combination of values for the parameters in Table 6.
Do 500 times:
Draw K vectors of counts for the three mutually exclusive categories implied by the two outcomes (comparator arms):; F_j , k_ = ( F_j , k 1_ , F_j , k 2_ , F_j , k 3_ ) ~ M ( N_j_^( C )^ , ( γ_j , k 1_^( C )^ , γ_j , k 2_^( C )^ , γ_j , k 3_^( C )^ ) ) .; If those experiencing outcome 1 are a subset of those experiencing outcome 2: A _j,k1_ = F _j,k1_, and A _j,k2_ = F _j,k1_ + F _j,k2_.
Draw K vectors of study effects for outcomes 1 and 2 θ_j,k_ = (θ_j,k1_, θ_j,k2_)′ ~ N (θ, T), where T = diag(τ) R diag (τ)
Calculate the probabilities for the three categories of events in the treatment arms:; γ_j , k 1_^( T )^ = logit^- 1^ ( θ_j , k 1_ + logit ( γ_j , k 1_^( C )^ ) ) , γ_j , k 2_^( T )^ = logit^- 1^ ( θ_j , k 1_ + logit ( γ_j , k 1_^( C )^ + γ_j , k 2_^( C )^ ) ) - γ_j , k 1_^( T )^ , with γ_j , k 3_^( T )^ = 1 - γ_j , k 1_^( T )^ - γ_j , k 2_^( T )^ .; If γ_j , k 3_^( T )^ ≤ 0 , set; γ_j , k 3_^( T )^ : = (10^- 4^)/(γ_j , k 1_^( T )^ + γ_j , k 2_^( T )^ + 10^- 4^) , γ_j , k 2_^( T )^ : = (γ_j , k 2_^( T )^)/(γ_j , k 1_^( T )^ + γ_j , k 2_^( T )^ + 10^- 4^) , and γ_j , k 1_^( T )^ : = (γ_j , k 1_^( T )^)/(γ_j , k 1_^( T )^ + γ_j , k 2_^( T )^ + 10^- 4^) .
Draw K vectors of counts for the three mutually exclusive categories implied by the two outcomes (treatment arms):; G_j , k_ = ( G_j , k 1_ , G_j , k 2_ , G_j , k 3_ ) ~ M ( N_j_^( T )^ , ( γ_j , k 1_^( T )^ , γ_j , k 2_^( T )^ , γ_j , k 3_^( T )^ ) ) .; Then B _j,k1_ = G _j,k1_, and B _j,k2_ = G _j,k1_ + G _j,k2_.

We verified the fidelity of the simulations by comparing the means and covariance matrices of the empirical distributions versus the simulation parameters for the study effects (θ_j,1_, θ_j,2_)’ and the proportions of events in the control arms.

### Metrics

The main aim of the simulation study is to illustrate comparisons of results from univariate and multivariate meta-analysis. Nevertheless, we calculated the mean squared error (MSE), the bias and the coverage probability for all examined methods (Table 9). We report these metrics for each outcome for analyses using the bivariate random effects method. Additional results are available from the authors.

Table 9 Definition of MSE, bias and coverage probability

Metric | Formula | Description | Comment
Mean squared error (MSE) | (1)/(500) Σ_i = 1_^500^ ( θ^_j , 1 i_ - θ_j , 1_ )^2^ (1)/(500) Σ_i = 1_^500^ ( θ^_j , 2 i_ - θ_j , 2_ )^2^ | The average squared difference between the true (simulated) mean and its estimate across the 500 simulation replicates in scenario j. | - Desirable to have MSE near zero.; - MSE can be high even if bias is 0, because positive and negative deviations of the estimates from the true mean do not cancel out.; - MSE is the sum of the variance of an estimate plus the square of its bias.
Bias | (1)/(500) Σ_i = 1_^500^ ( θ^_j , 1 i_ - θ_j , 1_ ) (1)/(500) Σ_i = 1_^500^ ( θ^_j , 2 i_ - θ_j , 2_ ) | The average difference between the true (simulated) mean and its estimate across the 500 simulation replicates in scenario j. | - Desirable to have bias near zero.
Coverage probability | (1)/(500) Σ_i = 1_^500^ I ( θ_j , 1_ ∈ [ 95 % CI of θ^_j , 1 i_ ] ) (1)/(500) Σ_i = 1_^500^ I ( θ_j , 2_ ∈ [ 95 % CI of θ^_j , 2 i_ ] ) | The proportion of times the 95% confidence interval of the estimated summary mean contains the true value. | - Desirable to have coverage near 95%.; - Coverage higher than 95% indicates an inefficient estimator; - Coverage less than 95% indicates an inaccurate estimator

θ̂_j,1_i stands for the meta-analysis estimate in draw i, and analogously for the other outcome.