# Background

The growing number of treatment choices, as well as the rapid escalation in the cost of health care, has spawned a need for scientifically rigorous comparisons of the efficacy and safety of drugs, devices and treatments in clinical practice. To date, most quantitative comparisons carried out by the Evidence Based Practice Centers (EPCs) funded by the Agency for Healthcare Research and Quality (AHRQ) have relied on traditional meta-analysis comparing two treatments with respect to a single outcome. However, many questions involve multiple outcomes. Standard assessments have approached these questions with separate meta-analyses, leading to a plethora of analyses to interpret without any quantitatively rigorous methods for integrating them. As these are multivariate problems, multivariate statistical methods offer a solution.1–4

Arguably, joint analysis of all relevant information may be preferable to separate analyses that use only a subset of the available information. For example, imagine that we have K studies comparing statins versus no statins for the outcomes of cardiac and noncardiac mortality. The usual approach is to perform two separate meta-analyses: one for cardiac mortality and one for noncardiac mortality. However, both outcomes are evaluated in the same patients (same studies), and are thus stochastically dependent (correlated). Intuitively, knowing something about one outcome tells us something about the other. In the previous example, if too many people die of cardiac causes, fewer people are at risk of dying of noncardiac causes: the proportions dying of the two mutually exclusive causes are negatively correlated. By analyzing the two outcomes jointly we can capitalize on these correlations—an opportunity that is lost with separate, univariate meta-analyses.2,5

Statistical methods for simultaneously analyzing multiple outcomes have appeared mainly in the past decade, along with applications to important problems. 2–11 Because they are new, these methods have not migrated into standard clinical research and remain the province of experts. Therefore the empirical evidence base for comparing multivariate meta-analysis of multiple outcomes or multiple follow-ups versus separate univariate meta-analyses is limited. Such empirical data are useful for making informed methodological recommendations regarding the use of multivariate versus univariate meta-analysis in applied systematic review and technology assessment. For example, if the numerical difference in the summary effects and their confidence intervals is always very small, the choice between univariate and multivariate meta-analysis has more academic than practical interest. If nonnegligible differences are common, recommendations can differ.

In this project we perform an empirical evaluation of separate (univariate) versus joint (multivariate) meta-analysis for comparing two treatments with respect to two or more categorical outcomes using real data from the Cochrane Library of Systematic Reviews. We supplement the empirical observations with a simulation study of a large number of scenarios representative of actual analyses.

## Project Aims

This project has three aims:

- Aim 1: Assemble a database of examples from the Cochrane Library of Systematic Reviews that can be analyzed with multivariate meta-analyses using only information reported in the reviews. (Cochrane systematic reviews perform only univariate meta-analysis.)
- Aim 2: Perform an empirical comparison of results with univariate versus multivariate meta-analysis for the database of Aim 1.
- Aim 3: Perform illustrative simulation analyses to compare multivariate and separate univariate meta-analyses for the case of two categorical outcomes that have a mutually exclusive relationship, or an is-subset-of relationship.

Aim 1 provides data for the quantitative calculations of Aim 2 and informs the choice of parameters for the simulations of Aim 3.