# Formulas, Figures, and Tables

## Formulas for variances and covariances of log odds ratios for mutually exclusive outcomes in study k

Dropping the study index we write p_1_ = π̂_1_ and p_2_ = π̂_2_ for the estimates of the proportions for the two mutually exclusive outcomes. Then:

θ^_1_ = log ( (p_1_^( T )^)/(1 - p_1_^( T )^) ) - log ( (p_1_^( C )^)/(1 - p_1_^( C )^) ) , θ^_2_ = log ( (p_2_^( T )^)/(1 - p_2_^( T )^) ) - log ( (p_2_^( C )^)/(1 - p_2_^( C )^) ) , v a^ r ( θ^_1_ ) = (1)/(N^( T )^ p_1_^( T )^ ( 1 - p_1_^( T )^ )) + (1)/(N^( C )^ p_1_^( C )^ ( 1 - p_1_^( C )^ )) , v a^ r ( θ^_2_ ) = (1)/(N^( T )^ p_2_^( T )^ ( 1 - p_2_^( T )^ )) + (1)/(N^( C )^ p_2_^( C )^ ( 1 - p_2_^( C )^ )) , and c o^ v ( θ^_1_ , θ^_2_ ) = - (1)/(N^( T )^ ( 1 - p_1_^( T )^ ) ( 1 - p_2_^( T )^ )) - (1)/(N^( C )^ ( 1 - p_1_^( C )^ ) ( 1 - p_2_^( C )^ )) .

## Formulas for variances and covariances of log odds ratios for outcomes that have an is-subset-of relationship in study k

Dropping the study index we write l_1_ = λ̂_1_ and l_2_ = λ̂_2_. The number of those experiencing the first outcome (indexed by 1) is a subset of those experiencing the second outcome (indexed by 2). Then:

θ^_1_ = log ( (l_1_^( T )^)/(1 - l_1_^( T )^) ) - log ( (l_1_^( C )^)/(1 - l_1_^( C )^) ) , θ^_2_ = log ( (l_2_^( T )^)/(1 - l_2_^( T )^) ) - log ( (l_2_^( C )^)/(1 - l_2_^( C )^) ) , v a^ r ( θ^_1_ ) = (1)/(N^( T )^ l_1_^( T )^ ( 1 - l_1_^( T )^ )) + (1)/(N^( C )^ l_1_^( C )^ ( 1 - l_1_^( C )^ )) , v a^ r ( θ^_2_ ) = (1)/(N^( T )^ l_2_^( T )^ ( 1 - l_2_^( T )^ )) + (1)/(N^( C )^ l_2_^( C )^ ( 1 - l_2_^( C )^ )) , and c o^ v ( θ^_1_ , θ^_2_ ) = (1)/(N^( T )^ l_1_^( T )^ ( 1 - l_2_^( T )^ )) + (1)/(N^( C )^ l_1_^( C )^ ( 1 - l_2_^( C )^ )) .

## Priors for Bayesian analyses

The true probabilities in the controls are assigned flat Dirichlet priors. For mutually exclusive outcomes:

( π_k 1_^( C )^ , … , π_k M_^( C )^ ) ~ D ( 1 , … , 1 ) Appendix. 19

For outcomes with an is-subset-of relationship, we assign priors to the probabilities for the mutually exclusive categories implied by the outcomes:

( γ_k 1_^( C )^ , … , γ_k M_^( C )^ ) ~ D ( 1 , … , 1 ) Appendix. 20

The true between-study means (the elements of Θ) are assigned independent normal priors

θ_m_ ~ N ( 0 , 10^5^ ) . Appendix. 21

To assign priors for the covariance matrix T we use the factorization T = diag(τ) R diag(τ). We assign independent uniform priors to the elements of τ:

τ_m_ ~ U ( 10^- 4^ , 2 ) Appendix. 22

The priors for R must guarantee that the matrix is positive definite with elements between −1 and 1. Further, because the posterior distributions for the elements of R with uninformative priors were very wide, we performed analyses with uninformative and relatively informative priors.

### For M =2

We have a single correlation coefficient ρ_12_ = ρ. As noninformative prior we chose the uniform

ρ ~ U ( - 0.9999 , 0.9999 ) . Appendix. 23

For outcomes with an is-subset-of relationship, it is likely that ρ takes mostly positive values. We therefore repeated analyses by assigning the following prior to the Fisher-transformed correlation coefficient:

tanh ( ρ ) ~ N ( 0.5493 , 0.6633 ) Appendix. 24

where the mean corresponds to a correlation coefficient of 0.50, and the variance is such that 75% of the drawn values are positive

0.5493 = tanh^−1^ (0.50), and Appendix. 25

0.6633 = (tanh(0.50)/Φ^−1^(0.25))^2^, with Appendix. 26

Φ^−1^(·) being the inverse cumulative distribution function for the standard normal. For mutually exclusive outcomes we do not anticipating a specific sign for the correlation coefficient, and thus we used only uninformative priors.

### For M =3

We follow Lu and Ades1 in factorizing R using the Cholesky decomposition for square symmetric matrices R = U′U, and in assigning specially constructed priors to the elements of the upper triangular matrix U (this is the spherical parameterization of Pinheiro and Bates2):

U = [ 1 cos ( φ_1_ ) cos ( φ_2_ ) 0 sin ( φ_1_ ) sin ( φ_2_ ) cos ( φ_3_ ) 0 0 sin ( φ_2_ ) sin ( φ_3_ ) ] Appendix. 27

Setting uniform independent priors for φ_l_ (l = 1,2,3) in the interval 0 to π = 3.14159... is an option for obtaining a prior for R in which all elements are between −1 and 1 and positive definitiveness is guaranteed

φ_l_ ~ U ( 0 , π ) Appendix. 28

To restrict the elements of R to positive values use:

φ_l_ ~ U ( 0 , π / 2 ) . Appendix. 29

See Lu and Ades1 for a short discussion of the implied density of the elements of R using the priors above. Nevertheless, the examined priors for the elements of R do not result in appreciable differences in the posterior distributions for the meta-analysis means. See Pinheiro and Bates2 for a discussion of additional parameterizations.

## Fitting the normal approximation model when at least one study has a singular covariance matrix

It is possible that the calculated covariance matrix of study k is singular. In a bivariate meta-analysis a study will have a singular covariance matrix if p_k , 1_^( T )^ = p_k , 1_^( C )^ = p_k , 2_^( T )^ = p_k , 2_^( C )^ = 0.5 for mutually exclusive outcomes; and if l_k , 1_^( T )^ = l_k , 2_^( T )^ and l_k , 1_^( C )^ = l_k , 2_^( C )^ for outcomes with an is-subset-of relationship. Singular covariance matrices cannot be inverted.^a^ To make calculations possible, one option is to keep only one outcome in the offending study or studies. Another option is to keep all outcomes and to use a ridge regression approach. Ridge regression is a form of regularized regression where a positive number ɛ_ridge_ (regularizing coefficient or regularizer) is added to the eigenvalues of the singular covariance matrices of offending studies.

a A similar concern pertains to studies with near singular covariance matrices, in that their inverses are numerically unstable. The same regularized regression can be used to correct near singular matrices. In this work we did not check for near-singular matrices nor made any corrections for them.

Let W be the inverse of the covariance matrix of the multivariate meta-analysis summary log odds ratios Θ with fixed effects. Then Θ, and the determinant D(ɛ_ridge_) and the trace Tr(ɛ_ridge_) of W are functions of ɛ_ridge_. One selects the minimum ɛ_ridge_ so that D(ɛ_ridge_), Tr(ɛ_ridge_) and the elements of Θ are stable.

For example, in topic 2 in the main report (comparison between sirolimus-eluting and bare metal stents for acute cardiac disease) the STRATEGY trial has a singular covariance matrix. The outcomes of interest are the number of major cardiac events at 6 and 12 months. No additional events were observed between 6 and 12 months in either arm, and l_STRATEGY , 1_^( T )^ = l_STRATEGY , 2_^( T )^ and l_STRATEGY , 1_^( C )^ = l_STRATEGY , 2_^( C )^ . The (uncorrected) sampling covariance matrix is calculated as

S_STRATEGY_ = [ .1289655 .1289655 .1289655 ] ,

and is singular. The corrected covariance matrix S_STRATEGY_ (ɛ_ridge_) is obtained by adding ɛ_ridge_ to the eigenvalues of S_STRATEGY_. It is easy to show that

S_STRATEGY_ ( ɛ_ridge_ ) = S_STRATEGY_ + I ɛ_ridge_ = [ .1289655 + ɛ_ridge_ .1289655 .1289655 + ɛ_ridge_ ] ,

where I is the identity matrix. We examine the plots of D(ɛ_ridge_) (Appendix Figure 1), Tr(ɛ_ridge_) (Appendix Figure 2), and Φ (Appendix Figure 3) to select a value for ɛ_ridge_. An infinitely large ɛ_ridge_ is equivalent to excluding STRATEGY from both outcomes in the meta-analysis. The aim is to select the minimum value for which the quantities in the figures have stabilized.

Appendix Figure 1 Relationship between the determinant of the inverse covariance matrix of the fixed effects multivariate meta-analysis estimates W as a function of ɛ_ridge_ (topic 2)

Appendix Figure 1 plots (as an example) the relationship between the determinant of the inverse covariance matrix of the fixed effects multivariate meta-analysis estimates as a function of the regularizing coefficient for topic 2. The used and suggested regularizing coefficient in this example were both 10.23293.

Appendix Figure 2 Relationship between the trace of the inverse covariance matrix of the fixed effects multivariate meta-analysis estimates W as a function of ɛ_ridge_ (topic 2)

Appendix Figure 2 plots (as an example) the relationship between the trace of the inverse covariance matrix of the fixed effects multivariate meta-analysis estimates as a function of the regularizing coefficient for topic 2. The used and suggested regularizing coefficient in this example were both 10.23293.

Appendix Figure 3 Relationship between the summary log odds ratios from fixed effects multivariate meta-analysis as a function of ^ɛ_ridge_^ (topic 2)

Appendix Figure 3 plots (as an example) the relationship between the summary log odds ratios from the fixed effects multivariate meta-analysis estimates as a function of the regularizing coefficient for topic 2. The used and suggested regularizing coefficient in this example were both 10.2.

We devised a heuristic for selecting the value of ɛ_ridge_ to enhance consistency in calculations across topics. We calculated the average of the absolute values of the smoothed numerical derivatives (slopes) of D(ɛ_ridge_), Tr(ɛ_ridge_), and of each summary log odds ratio with respect to ɛ. The heuristic proposes to use the ɛ that corresponds to an average absolute slope 1.7, i.e., a tangent angle of 60 degrees (Appendix Figure 4).

Appendix Figure 4 Heuristic for picking the value of ɛ_ridge_ (topic 2)

Appendix Figure 4 plots (as an example) the heurisitc for picking the value of the regularizing coeficient for topic 2. The used and suggested regularizing coefficient in this example were both 10.23293.

## Additional Results (Tables)

Appendix Table 1 Estimates with univariate and multivariate meta-analysis using normal approximation models in topics 1 through 43 (random effects)

Topic | Univariate exp (θ̂_1_) | Univariate exp (θ̂_2_) | Univariate exp (θ̂_1_ − θ̂_2_) | Multivariate exp (θ̂_1_) | Multivariate exp (θ̂_2_) | Multivariate exp (θ̂_1_ − θ̂_2_)
1 | 0.591 (0.484, 0.723) | 0.651 (0.472, 0.899) | 0.908 (0.620, 1.331) | 0.590 (0.496, 0.702) | 0.666 (0.517, 0.859) | 0.885 (0.730, 1.074)
2 | 0.294 (0.229, 0.377) | 0.339 (0.264, 0.435) | 0.868 (0.610, 1.235) | 0.324 (0.249, 0.421) | 0.303 (0.235, 0.389) | 1.071 (0.954, 1.201)
3 | 1.833 (1.354, 2.481) | 1.618 (1.099, 2.383) | 1.133 (0.692, 1.855) | 1.831 (1.208, 2.774) | 1.460 (1.007, 2.116) | 1.254 (0.985, 1.596)
4 | 1.132 (0.692, 1.852) | 0.938 (0.664, 1.326) | 1.206 (0.661, 2.202) | 1.162 (0.690, 1.957) | 0.942 (0.650, 1.365) | 1.233 (0.757, 2.010)
5 | 0.788 (0.483, 1.285) | 0.789 (0.531, 1.174) | 0.998 (0.532, 1.873) | 0.851 (0.545, 1.330) | 0.761 (0.495, 1.171) | 1.118 (0.618, 2.020)
6 | 0.931 (0.569, 1.522) | 0.885 (0.612, 1.281) | 1.051 (0.568, 1.947) | 0.966 (0.606, 1.542) | 0.876 (0.601, 1.277) | 1.103 (0.802, 1.517)
7 | 0.486 (0.299, 0.791) | 0.354 (0.215, 0.583) | 1.373 (0.684, 2.755) | 0.510 (0.313, 0.832) | 0.373 (0.230, 0.606) | 1.368 (0.880, 2.127)
8 | 0.666 (0.298, 1.492) | 0.845 (0.655, 1.091) | 0.788 (0.338, 1.840) | 0.699 (0.303, 1.613) | 0.855 (0.651, 1.123) | 0.818 (0.373, 1.795)
9 | 1.922 (1.402, 2.634) | 1.021 (0.848, 1.231) | 1.881 (1.303, 2.716) | 1.794 (1.301, 2.475) | 1.055 (0.867, 1.283) | 1.701 (1.252, 2.312)
10 | 0.871 (0.762, 0.995) | 0.836 (0.745, 0.937) | 1.042 (0.873, 1.243) | 0.822 (0.732, 0.923) | 0.839 (0.751, 0.937) | 0.980 (0.925, 1.038)
11 | 1.003 (0.762, 1.320) | 1.137 (0.665, 1.945) | 0.882 (0.482, 1.612) | 0.990 (0.733, 1.337) | 1.092 (0.667, 1.785) | 0.907 (0.692, 1.190)
12 | 0.585 (0.430, 0.796) | 0.629 (0.451, 0.878) | 0.930 (0.589, 1.469) | 0.622 (0.463, 0.834) | 0.627 (0.468, 0.842) | 0.991 (0.883, 1.111)
13 | 0.790 (0.640, 0.974) | 0.801 (0.693, 0.926) | 0.985 (0.763, 1.273) | 0.795 (0.657, 0.961) | 0.830 (0.708, 0.973) | 0.958 (0.837, 1.095)
14 | 0.809 (0.607, 1.077) | 0.852 (0.657, 1.106) | 0.949 (0.644, 1.397) | 0.853 (0.639, 1.138) | 0.912 (0.711, 1.169) | 0.935 (0.769, 1.138)
15 | 0.377 (0.162, 0.880) | 0.706 (0.461, 1.079) | 0.535 (0.206, 1.386) | 0.389 (0.163, 0.927) | 0.673 (0.456, 0.994) | 0.577 (0.311, 1.072)
16 | 0.386 (0.262, 0.568) | 0.530 (0.443, 0.633) | 0.728 (0.474, 1.117) | 0.421 (0.317, 0.560) | 0.529 (0.444, 0.631) | 0.796 (0.677, 0.936)
17 | 0.342 (0.198, 0.589) | 0.517 (0.367, 0.728) | 0.661 (0.346, 1.263) | 0.326 (0.185, 0.576) | 0.519 (0.374, 0.720) | 0.629 (0.392, 1.011)
18 | 0.358 (0.240, 0.534) | 0.281 (0.216, 0.366) | 1.273 (0.785, 2.062) | 0.436 (0.311, 0.610) | 0.281 (0.216, 0.366) | 1.552 (1.238, 1.946)
19 | 11.163 (5.810, 21.447) | 1.943 (0.683, 5.534) | 5.744 (1.651, 19.989) | 10.932 (5.797, 20.615) | 1.848 (0.666, 5.123) | 5.917 (2.034, 17.212)
20 | 5.529 (2.099, 14.569) | 3.296 (1.738, 6.254) | 1.677 (0.522, 5.394) | 5.668 (2.515, 12.774) | 3.670 (1.782, 7.561) | 1.544 (0.761, 3.132)
21 | 0.722 (0.572, 0.912) | 0.568 (0.486, 0.663) | 1.273 (0.961, 1.685) | 0.780 (0.613, 0.992) | 0.551 (0.464, 0.654) | 1.415 (1.079, 1.856)
22 | 0.985 (0.608, 1.594) | 1.096 (0.721, 1.667) | 0.899 (0.474, 1.702) | 0.964 (0.575, 1.615) | 1.161 (0.701, 1.924) | 0.830 (0.636, 1.083)
23 | 1.065 (0.632, 1.794) | 0.875 (0.643, 1.190) | 1.218 (0.665, 2.231) | 1.032 (0.573, 1.860) | 0.868 (0.629, 1.198) | 1.190 (0.672, 2.107)
24 | 0.753 (0.366, 1.552) | 0.815 (0.428, 1.551) | 0.925 (0.351, 2.434) | 0.786 (0.340, 1.818) | 0.740 (0.343, 1.598) | 1.062 (0.729, 1.546)
25 | 1.269 (0.576, 2.799) | 1.848 (1.060, 3.222) | 0.687 (0.261, 1.811) | 1.201 (0.601, 2.402) | 1.979 (1.061, 3.693) | 0.607 (0.358, 1.030)
26 | 0.467 (0.404, 0.540) | 0.315 (0.266, 0.374) | 1.481 (1.183, 1.854) | 0.502 (0.443, 0.570) | 0.347 (0.299, 0.401) | 1.450 (1.231, 1.707)
27 | 0.452 (0.398, 0.513) | 0.397 (0.344, 0.459) | 1.137 (0.938, 1.378) | 0.427 (0.367, 0.497) | 0.379 (0.317, 0.454) | 1.126 (0.918, 1.380)
28 | 0.342 (0.290, 0.403) | 0.278 (0.229, 0.338) | 1.228 (0.952, 1.585) | 0.352 (0.299, 0.414) | 0.272 (0.228, 0.325) | 1.292 (1.113, 1.500)
29 | 0.617 (0.519, 0.734) | 0.544 (0.461, 0.641) | 1.136 (0.895, 1.442) | 0.638 (0.542, 0.751) | 0.560 (0.478, 0.656) | 1.140 (1.024, 1.268)
30 | 0.237 (0.194, 0.289) | 0.244 (0.200, 0.298) | 0.971 (0.732, 1.288) | 0.248 (0.204, 0.302) | 0.176 (0.138, 0.224) | 1.412 (1.190, 1.676)
31 | 0.443 (0.333, 0.589) | 0.442 (0.320, 0.610) | 1.002 (0.651, 1.544) | 0.473 (0.364, 0.615) | 0.461 (0.344, 0.618) | 1.026 (0.781, 1.348)
32 | 0.637 (0.517, 0.784) | 0.410 (0.289, 0.580) | 1.554 (1.035, 2.334) | 0.653 (0.520, 0.821) | 0.423 (0.271, 0.661) | 1.544 (0.951, 2.507)
33 | 0.418 (0.241, 0.723) | 0.458 (0.264, 0.794) | 0.913 (0.416, 2.003) | 0.410 (0.241, 0.698) | 0.314 (0.186, 0.532) | 1.305 (0.788, 2.160)
34 | 2.921 (2.102, 4.060) | 3.060 (1.991, 4.702) | 0.955 (0.554, 1.644) | 2.953 (2.081, 4.192) | 3.544 (2.307, 5.443) | 0.833 (0.574, 1.210)
35 | 0.810 (0.574, 1.143) | 0.589 (0.428, 0.811) | 1.374 (0.858, 2.201) | 0.813 (0.571, 1.157) | 0.568 (0.413, 0.782) | 1.431 (1.003, 2.041)
36 | 0.289 (0.161, 0.516) | 0.208 (0.118, 0.367) | 1.387 (0.613, 3.137) | 0.298 (0.170, 0.522) | 0.192 (0.114, 0.325) | 1.550 (1.012, 2.375)
37 | 1.233 (0.605, 2.513) | 1.414 (0.780, 2.565) | 0.872 (0.345, 2.206) | 1.079 (0.568, 2.050) | 1.433 (0.817, 2.512) | 0.753 (0.468, 1.212)
38 | 0.676 (0.431, 1.060) | 0.661 (0.493, 0.886) | 1.023 (0.596, 1.755) | 0.583 (0.399, 0.852) | 0.624 (0.446, 0.872) | 0.934 (0.771, 1.132)
39^*^ | 1.923 (0.986, 3.751) | 0.542 (0.351, 0.838) | 3.546 (1.594, 7.888) | 1.726 (0.995, 2.994) | 0.531 (0.337, 0.836) | 3.250 (1.258, 8.401)
40^*^ | 0.792 (0.453, 1.385) | 0.709 (0.417, 1.205) | 1.117 (0.517, 2.414) | 0.830 (0.477, 1.442) | 0.671 (0.389, 1.157) | 1.236 (0.626, 2.441)
41^*^ | 1.223 (1.069, 1.398) | 0.891 (0.764, 1.039) | 1.373 (1.118, 1.685) | 1.261 (1.071, 1.485) | 0.843 (0.711, 0.998) | 1.497 (1.099, 2.038)
42^*^ | 0.908 (0.706, 1.167) | 0.972 (0.759, 1.244) | 0.934 (0.655, 1.332) | 0.869 (0.631, 1.197) | 0.950 (0.720, 1.252) | 0.915 (0.619, 1.352)
43^*^ | 1.211 (1.077, 1.362) | 0.921 (0.780, 1.087) | 1.315 (1.069, 1.618) | 1.217 (1.086, 1.365) | 0.929 (0.798, 1.082) | 1.310 (1.033, 1.661)

Shown are means and 95% confidence intervals.

* These topics refer to mutually exclusive outcomes.

Appendix Table 2 Estimates with univariate and multivariate meta-analysis using normal approximation models in topics 44 and 45 (random effects)

Analysis or Topic | exp (θ̂_1_) | exp (θ̂_2_) | exp (θ̂_3_) | exp (θ̂_1_ − θ̂_2_) | exp (θ̂_1_ − θ̂_3_) | exp (θ̂_2_ − θ̂_3_)
Univariate
44 | 1.957 (1.201, 3.189) | 1.620 (1.089, 2.411) | 1.586 (1.073, 2.343) | 1.208 (0.644, 2.267) | 1.234 (0.660, 2.306) | 1.022 (0.585, 1.784)
45 | 1.195 (0.601, 2.374) | 1.137 (0.704, 1.837) | 1.058 (0.719, 1.557) | 1.050 (0.451, 2.445) | 1.129 (0.512, 2.488) | 1.075 (0.577, 2.002)
Multivariate
44 | 1.653 (1.107, 2.467) | 1.941 (1.202, 3.133) | 1.672 (1.091, 2.563) | 0.852 (0.564, 1.286) | 0.988 (0.674, 1.450) | 1.161 (0.758, 1.777)
45 | 1.034 (0.673, 1.590) | 1.099 (0.613, 1.968) | 1.067 (0.696, 1.637) | 0.941 (0.739, 1.199) | 0.969 (0.872, 1.076) | 1.029 (0.780, 1.358)

Shown are means and 95% confidence intervals.

Appendix Table 3 Estimates with univariate and multivariate meta-analysis using normal approximation models in topics 1 through 43 (fixed effects)

Topic | Univariate exp (θ̂_1_) | Univariate exp (θ̂_2_) | Univariate exp (θ̂_1_ − θ̂_2_) | Multivariate exp (θ̂_1_) | Multivariate exp (θ̂_2_) | Multivariate exp (θ̂_1_ − θ̂_2_)
1 | 0.591 (0.498, 0.702) | 0.643 (0.529, 0.781) | 0.920 (0.708, 1.195) | 0.590 (0.501, 0.696) | 0.650 (0.553, 0.765) | 0.908 (0.823, 1.002)
2 | 0.294 (0.235, 0.368) | 0.344 (0.279, 0.423) | 0.856 (0.629, 1.163) | 0.343 (0.282, 0.419) | 0.321 (0.266, 0.388) | 1.070 (0.956, 1.198)
3 | 1.544 (1.393, 1.712) | 1.297 (1.186, 1.419) | 1.190 (1.038, 1.365) | 1.545 (1.395, 1.710) | 1.291 (1.181, 1.411) | 1.197 (1.106, 1.295)
4 | 1.132 (0.692, 1.852) | 0.938 (0.664, 1.326) | 1.206 (0.661, 2.202) | 1.114 (0.688, 1.806) | 0.943 (0.667, 1.334) | 1.181 (0.778, 1.793)
5 | 0.763 (0.548, 1.062) | 0.789 (0.552, 1.129) | 0.966 (0.594, 1.573) | 0.783 (0.563, 1.088) | 0.804 (0.566, 1.143) | 0.973 (0.669, 1.416)
6 | 0.931 (0.569, 1.522) | 0.886 (0.614, 1.277) | 1.051 (0.569, 1.943) | 0.968 (0.615, 1.525) | 0.877 (0.607, 1.265) | 1.105 (0.805, 1.517)
7 | 0.486 (0.299, 0.791) | 0.352 (0.222, 0.558) | 1.380 (0.707, 2.696) | 0.509 (0.315, 0.822) | 0.371 (0.235, 0.583) | 1.373 (0.892, 2.114)
8 | 0.716 (0.362, 1.418) | 0.845 (0.655, 1.091) | 0.847 (0.408, 1.760) | 0.751 (0.393, 1.435) | 0.846 (0.656, 1.092) | 0.887 (0.478, 1.648)
9 | 1.922 (1.402, 2.634) | 1.018 (0.851, 1.218) | 1.888 (1.313, 2.714) | 1.679 (1.247, 2.259) | 1.032 (0.863, 1.234) | 1.627 (1.256, 2.107)
10 | 0.871 (0.762, 0.995) | 0.836 (0.745, 0.937) | 1.042 (0.873, 1.243) | 0.817 (0.729, 0.915) | 0.841 (0.754, 0.938) | 0.971 (0.928, 1.017)
11 | 0.984 (0.826, 1.172) | 1.184 (0.955, 1.468) | 0.831 (0.629, 1.097) | 0.986 (0.828, 1.173) | 1.123 (0.915, 1.378) | 0.878 (0.741, 1.041)
12 | 0.655 (0.532, 0.807) | 0.729 (0.600, 0.885) | 0.899 (0.674, 1.199) | 0.695 (0.569, 0.849) | 0.709 (0.589, 0.854) | 0.980 (0.875, 1.098)
13 | 0.788 (0.691, 0.900) | 0.801 (0.693, 0.926) | 0.984 (0.808, 1.198) | 0.784 (0.691, 0.891) | 0.844 (0.739, 0.963) | 0.929 (0.844, 1.023)
14 | 0.778 (0.649, 0.932) | 0.857 (0.721, 1.018) | 0.908 (0.707, 1.166) | 0.820 (0.696, 0.967) | 0.914 (0.779, 1.073) | 0.897 (0.798, 1.010)
15 | 0.935 (0.712, 1.228) | 0.932 (0.790, 1.099) | 1.003 (0.728, 1.382) | 0.880 (0.677, 1.144) | 0.934 (0.792, 1.102) | 0.942 (0.751, 1.182)
16 | 0.398 (0.333, 0.476) | 0.524 (0.471, 0.583) | 0.760 (0.616, 0.937) | 0.417 (0.355, 0.490) | 0.525 (0.472, 0.584) | 0.794 (0.699, 0.902)
17 | 0.437 (0.331, 0.576) | 0.590 (0.495, 0.705) | 0.740 (0.532, 1.029) | 0.452 (0.352, 0.579) | 0.598 (0.502, 0.714) | 0.755 (0.626, 0.909)
18 | 0.358 (0.240, 0.534) | 0.281 (0.216, 0.366) | 1.273 (0.785, 2.062) | 0.436 (0.311, 0.610) | 0.281 (0.216, 0.366) | 1.552 (1.238, 1.946)
19 | 11.163 (5.810, 21.447) | 1.943 (0.683, 5.534) | 5.744 (1.651, 19.989) | 10.932 (5.797, 20.615) | 1.848 (0.666, 5.123) | 5.917 (2.034, 17.212)
20 | 4.051 (2.483, 6.609) | 3.272 (1.853, 5.780) | 1.238 (0.580, 2.643) | 4.348 (2.715, 6.964) | 3.271 (1.859, 5.755) | 1.329 (0.750, 2.355)
21 | 0.722 (0.572, 0.912) | 0.585 (0.516, 0.663) | 1.235 (0.948, 1.609) | 0.793 (0.633, 0.993) | 0.585 (0.516, 0.663) | 1.356 (1.101, 1.670)
22 | 0.985 (0.608, 1.594) | 1.096 (0.721, 1.667) | 0.899 (0.474, 1.702) | 0.928 (0.580, 1.483) | 1.109 (0.729, 1.688) | 0.836 (0.657, 1.065)
23 | 1.059 (0.662, 1.695) | 0.880 (0.663, 1.170) | 1.203 (0.695, 2.084) | 0.848 (0.546, 1.316) | 0.888 (0.668, 1.180) | 0.955 (0.671, 1.358)
24 | 0.753 (0.366, 1.552) | 0.815 (0.428, 1.551) | 0.925 (0.351, 2.434) | 0.862 (0.434, 1.710) | 0.792 (0.414, 1.516) | 1.088 (0.783, 1.512)
25 | 1.239 (0.655, 2.344) | 1.644 (1.123, 2.406) | 0.753 (0.358, 1.586) | 1.081 (0.628, 1.862) | 1.708 (1.174, 2.485) | 0.633 (0.401, 0.999)
26 | 0.495 (0.460, 0.533) | 0.298 (0.266, 0.333) | 1.665 (1.457, 1.902) | 0.472 (0.439, 0.507) | 0.402 (0.367, 0.441) | 1.173 (1.092, 1.261)
27 | 0.463 (0.413, 0.519) | 0.433 (0.384, 0.487) | 1.070 (0.908, 1.261) | 0.432 (0.390, 0.479) | 0.437 (0.393, 0.485) | 0.990 (0.940, 1.043)
28 | 0.346 (0.298, 0.402) | 0.283 (0.240, 0.334) | 1.223 (0.979, 1.529) | 0.359 (0.311, 0.415) | 0.279 (0.241, 0.322) | 1.289 (1.122, 1.481)
29 | 0.617 (0.519, 0.734) | 0.544 (0.461, 0.641) | 1.136 (0.895, 1.442) | 0.613 (0.527, 0.714) | 0.544 (0.467, 0.633) | 1.128 (1.015, 1.254)
30 | 0.248 (0.209, 0.294) | 0.244 (0.200, 0.298) | 1.017 (0.782, 1.324) | 0.265 (0.225, 0.312) | 0.197 (0.166, 0.235) | 1.343 (1.156, 1.560)
31 | 0.471 (0.377, 0.589) | 0.461 (0.356, 0.596) | 1.023 (0.728, 1.439) | 0.496 (0.403, 0.611) | 0.484 (0.384, 0.611) | 1.025 (0.803, 1.307)
32 | 0.637 (0.517, 0.784) | 0.444 (0.339, 0.582) | 1.434 (1.019, 2.018) | 0.595 (0.486, 0.729) | 0.512 (0.400, 0.655) | 1.162 (0.938, 1.438)
33 | 0.531 (0.397, 0.710) | 0.569 (0.398, 0.814) | 0.933 (0.586, 1.484) | 0.539 (0.404, 0.719) | 0.373 (0.245, 0.568) | 1.445 (0.944, 2.212)
34 | 2.921 (2.102, 4.060) | 2.604 (1.843, 3.678) | 1.122 (0.695, 1.812) | 2.988 (2.156, 4.141) | 2.839 (2.066, 3.902) | 1.052 (0.808, 1.372)
35 | 0.810 (0.574, 1.143) | 0.589 (0.428, 0.811) | 1.374 (0.858, 2.201) | 0.789 (0.567, 1.097) | 0.560 (0.408, 0.770) | 1.408 (0.994, 1.993)
36 | 0.289 (0.161, 0.516) | 0.208 (0.118, 0.367) | 1.387 (0.613, 3.137) | 0.298 (0.170, 0.522) | 0.192 (0.114, 0.325) | 1.550 (1.012, 2.375)
37 | 1.233 (0.605, 2.513) | 1.414 (0.800, 2.500) | 0.872 (0.350, 2.170) | 1.079 (0.568, 2.050) | 1.433 (0.817, 2.512) | 0.753 (0.468, 1.212)
38 | 0.676 (0.435, 1.051) | 0.661 (0.493, 0.886) | 1.023 (0.601, 1.742) | 0.649 (0.471, 0.894) | 0.678 (0.503, 0.913) | 0.957 (0.794, 1.153)
39^*^ | 1.561 (1.213, 2.009) | 0.500 (0.375, 0.667) | 3.121 (2.124, 4.585) | 1.539 (1.203, 1.969) | 0.529 (0.398, 0.702) | 2.911 (1.876, 4.518)
40^*^ | 0.887 (0.647, 1.216) | 0.702 (0.445, 1.109) | 1.263 (0.725, 2.200) | 0.945 (0.691, 1.292) | 0.829 (0.529, 1.299) | 1.139 (0.599, 2.168)
41^*^ | 1.141 (1.050, 1.241) | 0.924 (0.827, 1.032) | 1.235 (1.075, 1.421) | 1.150 (1.059, 1.248) | 0.903 (0.814, 1.001) | 1.274 (1.075, 1.510)
42^*^ | 0.902 (0.732, 1.111) | 0.959 (0.767, 1.198) | 0.941 (0.692, 1.279) | 0.904 (0.734, 1.114) | 0.961 (0.769, 1.201) | 0.941 (0.690, 1.281)
43^*^ | 1.211 (1.077, 1.362) | 0.921 (0.790, 1.074) | 1.315 (1.081, 1.601) | 1.217 (1.086, 1.365) | 0.929 (0.798, 1.082) | 1.310 (1.033, 1.661)

Shown are means and 95% confidence intervals.

* These topics refer to mutually exclusive outcomes.

Appendix Table 4 Estimates with univariate and multivariate meta-analysis using normal approximation models in topics 44 and 45 (fixed effects)

Analysis or Topic | exp (θ̂_1_) | exp (θ̂_2_) | exp (θ̂_3_) | exp (θ̂_1_ − θ̂_2_) | exp (θ̂_1_ − θ̂_3_) | exp (θ̂_2_ − θ̂_3_)
Univariate
44 | 1.957 (1.201, 3.189) | 1.620 (1.089, 2.411) | 1.586 (1.073, 2.343) | 1.208 (0.644, 2.267) | 1.234 (0.660, 2.306) | 1.022 (0.585, 1.784)
45 | 1.355 (1.112, 1.651) | 1.201 (1.034, 1.394) | 1.200 (1.044, 1.378) | 1.128 (0.879, 1.448) | 1.129 (0.886, 1.439) | 1.001 (0.814, 1.230)
Multivariate
44 | 1.706 (1.164, 2.499) | 1.766 (1.142, 2.733) | 1.683 (1.153, 2.457) | 0.966 (0.721, 1.293) | 1.014 (0.802, 1.281) | 1.049 (0.728, 1.513)
45 | 1.190 (1.031, 1.375) | 1.327 (1.090, 1.616) | 1.218 (1.061, 1.399) | 0.897 (0.773, 1.040) | 0.977 (0.941, 1.014) | 1.089 (0.935, 1.268)

Shown are means and 95% confidence intervals.

Appendix Table 5 Estimates with univariate and multivariate meta-analysis using the binomial or multinomial likelihood in topics 1 through 43 (random effects)

Topic | Univariate exp (θ_1_) | Univariate exp (θ_2_) | Univariate exp (θ_1_ − θ_2_) | Multivariate exp (θ_1_) | Multivariate exp (θ_2_) | Multivariate exp (θ_1_ − θ_2_)
1 | 0.545 (0.382, 0.684) | 0.586 (0.346, 0.909) | 0.925 (0.526, 1.658) | 0.540 (0.409, 0.650) | 0.612 (0.448, 0.806) | 0.877 (0.693, 1.111)
2 | 0.259 (0.178, 0.344) | 0.261 (0.170, 0.368) | 0.993 (0.600, 1.648) | 0.287 (0.215, 0.368) | 0.301 (0.234, 0.373) | 0.964 (0.753, 1.131)
3 | 1.748 (1.356, 2.719) | 1.533 (1.145, 2.600) | 1.141 (0.633, 1.960) | 1.659 (1.312, 2.455) | 1.386 (1.066, 2.018) | 1.197 (0.877, 1.688)
4 | 0.934 (0.463, 1.605) | 0.767 (0.470, 1.143) | 1.220 (0.553, 2.534) | 0.851 (0.458, 1.451) | 0.793 (0.523, 1.168) | 1.072 (0.655, 1.681)
5 | 0.771 (0.455, 1.284) | 0.712 (0.400, 1.096) | 1.093 (0.547, 2.375) | 0.785 (0.467, 1.308) | 0.759 (0.432, 1.148) | 1.035 (0.610, 1.876)
6 | 0.602 (0.245, 1.067) | 0.495 (0.191, 0.816) | 1.234 (0.441, 3.663) | 0.520 (0.215, 0.915) | 0.572 (0.306, 0.923) | 0.889 (0.537, 1.281)
7 | 0.480 (0.275, 0.799) | 0.351 (0.205, 0.598) | 1.365 (0.644, 2.863) | 0.471 (0.278, 0.809) | 0.377 (0.223, 0.653) | 1.249 (0.713, 2.115)
8 | 0.477 (0.155, 1.100) | 0.818 (0.613, 1.112) | 0.577 (0.186, 1.413) | 0.474 (0.147, 1.139) | 0.814 (0.615, 1.126) | 0.579 (0.190, 1.340)
9 | 1.512 (1.090, 2.049) | 0.857 (0.697, 1.038) | 1.764 (1.215, 2.533) | 1.320 (0.977, 1.812) | 0.862 (0.716, 1.048) | 1.524 (1.186, 2.016)
10 | 0.869 (0.753, 1.004) | 0.839 (0.725, 0.976) | 1.035 (0.844, 1.273) | 0.795 (0.713, 0.878) | 0.802 (0.716, 0.872) | 0.994 (0.938, 1.053)
11 | 1.044 (0.781, 1.410) | 1.147 (0.643, 1.959) | 0.912 (0.495, 1.717) | 1.016 (0.757, 1.366) | 1.089 (0.646, 1.772) | 0.933 (0.682, 1.323)
12 | 0.528 (0.365, 0.722) | 0.549 (0.351, 0.774) | 0.964 (0.581, 1.649) | 0.539 (0.376, 0.700) | 0.591 (0.423, 0.751) | 0.920 (0.766, 1.060)
13 | 0.797 (0.635, 0.995) | 0.793 (0.657, 0.970) | 1.002 (0.742, 1.343) | 0.792 (0.651, 0.964) | 0.822 (0.705, 0.963) | 0.961 (0.816, 1.148)
14 | 0.822 (0.601, 1.169) | 0.776 (0.590, 1.088) | 1.060 (0.668, 1.651) | 0.854 (0.650, 1.156) | 0.908 (0.707, 1.188) | 0.938 (0.746, 1.208)
15 | 0.295 (0.094, 0.727) | 0.715 (0.401, 1.161) | 0.412 (0.121, 1.182) | 0.280 (0.102, 0.655) | 0.640 (0.404, 0.984) | 0.444 (0.185, 0.874)
16 | 0.361 (0.227, 0.559) | 0.489 (0.384, 0.627) | 0.736 (0.437, 1.207) | 0.371 (0.260, 0.510) | 0.500 (0.415, 0.594) | 0.744 (0.574, 0.928)
17 | 0.276 (0.116, 0.522) | 0.513 (0.329, 0.752) | 0.539 (0.210, 1.144) | 0.222 (0.089, 0.423) | 0.428 (0.274, 0.616) | 0.519 (0.248, 0.901)
18 | 0.305 (0.180, 0.470) | 0.223 (0.143, 0.320) | 1.378 (0.722, 2.518) | 0.324 (0.219, 0.465) | 0.244 (0.183, 0.323) | 1.327 (0.955, 1.769)
19 | 17.187 (7.959, 45.174) | 40.932 (4.547, 1710.109) | 0.424 (0.009, 4.781) | 14.565 (6.902, 34.201) | 13.113 (2.646, 123.898) | 1.120 (0.124, 5.449)
20 | 7.209 (2.704, 21.568) | 4.874 (1.931, 16.060) | 1.477 (0.327, 6.239) | 7.305 (3.179, 19.494) | 5.967 (2.770, 17.124) | 1.205 (0.513, 2.701)
21 | 0.596 (0.438, 0.761) | 0.514 (0.415, 0.602) | 1.163 (0.816, 1.598) | 0.599 (0.432, 0.767) | 0.520 (0.426, 0.610) | 1.158 (0.829, 1.519)
22 | 0.789 (0.464, 1.262) | 0.797 (0.489, 1.234) | 0.991 (0.503, 1.926) | 0.708 (0.449, 1.098) | 0.818 (0.542, 1.197) | 0.875 (0.656, 1.118)
23 | 0.845 (0.484, 1.406) | 0.699 (0.478, 0.956) | 1.209 (0.635, 2.293) | 0.739 (0.404, 1.248) | 0.699 (0.488, 0.948) | 1.050 (0.653, 1.680)
24 | 0.467 (0.158, 1.010) | 0.433 (0.179, 0.839) | 1.079 (0.309, 3.452) | 0.405 (0.167, 0.792) | 0.462 (0.228, 0.817) | 0.891 (0.480, 1.302)
25 | 1.096 (0.444, 2.499) | 1.460 (0.736, 3.251) | 0.743 (0.229, 2.182) | 1.060 (0.537, 2.117) | 1.634 (1.026, 2.979) | 0.635 (0.348, 1.125)
26 | 0.474 (0.407, 0.550) | 0.301 (0.246, 0.367) | 1.572 (1.226, 2.019) | 0.403 (0.351, 0.462) | 0.380 (0.330, 0.436) | 1.054 (1.001, 1.157)
27 | 0.448 (0.387, 0.511) | 0.380 (0.307, 0.459) | 1.177 (0.928, 1.517) | 0.401 (0.351, 0.449) | 0.394 (0.342, 0.444) | 1.013 (0.961, 1.105)
28 | 0.314 (0.264, 0.367) | 0.243 (0.198, 0.294) | 1.293 (0.998, 1.680) | 0.302 (0.255, 0.354) | 0.263 (0.223, 0.314) | 1.148 (0.978, 1.332)
29 | 0.626 (0.527, 0.745) | 0.515 (0.424, 0.623) | 1.216 (0.940, 1.572) | 0.564 (0.488, 0.657) | 0.542 (0.469, 0.627) | 1.039 (0.977, 1.132)
30 | 0.225 (0.181, 0.271) | 0.203 (0.157, 0.251) | 1.111 (0.819, 1.519) | 0.215 (0.177, 0.257) | 0.188 (0.153, 0.228) | 1.149 (0.957, 1.356)
31 | 0.434 (0.308, 0.586) | 0.336 (0.227, 0.509) | 1.287 (0.762, 2.096) | 0.449 (0.331, 0.578) | 0.441 (0.324, 0.590) | 1.018 (0.764, 1.326)
32 | 0.611 (0.443, 0.782) | 0.373 (0.220, 0.545) | 1.640 (0.989, 2.873) | 0.559 (0.381, 0.710) | 0.459 (0.298, 0.620) | 1.197 (0.936, 1.721)
33 | 0.415 (0.220, 0.719) | 0.400 (0.179, 0.740) | 1.045 (0.424, 2.763) | 0.421 (0.232, 0.707) | 0.389 (0.189, 0.671) | 1.096 (0.611, 1.937)
34 | 2.535 (1.864, 3.497) | 2.143 (1.530, 3.145) | 1.182 (0.722, 1.903) | 2.401 (1.776, 3.345) | 2.610 (1.838, 3.906) | 0.921 (0.659, 1.269)
35 | 0.792 (0.562, 1.108) | 0.577 (0.395, 0.840) | 1.378 (0.825, 2.271) | 0.637 (0.482, 0.853) | 0.574 (0.425, 0.776) | 1.112 (0.894, 1.441)
36 | 0.258 (0.142, 0.453) | 0.160 (0.086, 0.280) | 1.611 (0.716, 3.708) | 0.218 (0.122, 0.375) | 0.172 (0.103, 0.303) | 1.229 (0.790, 1.942)
37 | 1.169 (0.546, 2.481) | 1.263 (0.636, 2.507) | 0.922 (0.330, 2.559) | 1.019 (0.548, 2.061) | 1.334 (0.745, 2.442) | 0.772 (0.440, 1.377)
38 | 0.599 (0.299, 1.029) | 0.457 (0.230, 0.774) | 1.314 (0.552, 3.099) | 0.501 (0.344, 0.684) | 0.498 (0.359, 0.668) | 1.001 (0.841, 1.193)
39^*^ | 1.895 (0.987, 3.858) | 0.509 (0.336, 0.804) | 3.717 (1.686, 8.401) | 1.768 (0.980, 3.320) | 0.503 (0.330, 0.783) | 3.517 (1.417, 8.867)
40^*^ | 0.836 (0.453, 1.485) | 0.624 (0.365, 1.075) | 1.336 (0.596, 2.940) | 0.862 (0.460, 1.580) | 0.609 (0.344, 1.045) | 1.419 (0.646, 3.044)
41^*^ | 1.256 (1.090, 1.513) | 0.865 (0.690, 1.021) | 1.461 (1.160, 1.937) | 1.257 (1.092, 1.511) | 0.852 (0.691, 1.000) | 1.476 (1.137, 2.092)
42^*^ | 0.768 (0.456, 1.053) | 0.774 (0.483, 1.031) | 0.993 (0.553, 1.750) | 0.698 (0.386, 1.010) | 0.715 (0.416, 1.003) | 0.974 (0.531, 1.742)
43^*^ | 1.235 (1.079, 1.457) | 0.890 (0.708, 1.067) | 1.391 (1.106, 1.841) | 1.236 (1.092, 1.421) | 0.894 (0.730, 1.065) | 1.384 (1.074, 1.841)

Shown are posterior medians and 95% credible intervals. For topics 1 through 38 analyses used priors that provide information on the sign of the correlation coefficient at the between-study level. Topics 39 through 43 were analyzed using uninformative priors.

* These topics refer to mutually exclusive outcomes.

Appendix Table 6 Estimates with univariate and multivariate meta-analysis using the binomial or multinomial likelihood in topics 44 and 45 (random effects)

Analysis or Topic | exp (θ_1_) | exp (θ_2_) | exp (θ_3_) | exp (θ_1_ − θ_2_) | exp (θ_1_ − θ_3_) | exp (θ_2_ − θ_3_)
Univariate
44 | 1.765 (1.053, 2.856) | 1.412 (0.902, 2.132) | 1.378 (0.902, 2.089) | 1.250 (0.646, 2.412) | 1.279 (0.663, 2.430) | 1.023 (0.555, 1.860)
45 | 0.973 (0.371, 2.140) | 0.979 (0.511, 1.708) | 0.698 (0.359, 1.146) | 0.992 (0.329, 2.766) | 1.404 (0.475, 3.825) | 1.405 (0.623, 3.305)
Multivariate
44 | 1.578 (0.998, 2.535) | 1.441 (0.934, 2.151) | 1.492 (0.990, 2.185) | 1.099 (0.783, 1.638) | 1.074 (0.702, 1.644) | 0.975 (0.692, 1.330)
45 | 0.748 (0.381, 1.494) | 0.741 (0.450, 1.128) | 0.760 (0.463, 1.116) | 1.009 (0.672, 1.575) | 0.988 (0.628, 1.650) | 0.978 (0.834, 1.178)

Shown are posterior medians and 95% credible intervals. Analyses used mildly informative priors for the between-study correlation matrix.

Appendix Table 7 MSE, coverage and bias for random effects univariate meta-analysis averaging over τ_1_^2^ , τ_2_^2^ and ρ

K | N | exp (θ_1_) | exp (θ_1_) | MSE for (θ̂_1_ (×10^−3^) | MSE for (θ̂_2_ (×10^−3^) | Bias for (θ̂_1_ (×10^−3^) | Bias for (θ̂_2_ (×10^−3^) | Coverage (%) for (θ̂_1_ | Coverage (%) for (θ̂_2_
10 | 50 | 1 | 1 | 27.8 | 27.9 | −1.6 | 0.1 | 98.7 | 98.7
10 | 50 | 1 | 1.5 | 28.0 | 24.6 | −0.3 | −6.8 | 98.6 | 98.7
10 | 50 | 1.5 | 1 | 24.9 | 27.8 | −5.7 | −0.9 | 98.6 | 98.8
10 | 50 | 1.5 | 1.5 | 24.9 | 25.2 | −5.0 | −6.1 | 98.6 | 98.7
10 | 100 | 1 | 1 | 14.2 | 13.9 | −0.4 | −0.6 | 98.5 | 98.7
10 | 100 | 1 | 1.5 | 14.2 | 12.7 | 0.1 | −1.3 | 98.7 | 98.4
10 | 100 | 1.5 | 1 | 12.6 | 14.4 | −2.4 | −0.6 | 98.4 | 98.4
10 | 100 | 1.5 | 1.5 | 12.8 | 12.9 | −1.9 | −2.1 | 98.3 | 98.3
10 | 500 | 1 | 1 | 2.9 | 2.9 | −0.4 | 0.1 | 98.2 | 98.2
10 | 500 | 1 | 1.5 | 2.9 | 2.5 | 0.3 | −0.7 | 98.4 | 98.3
10 | 500 | 1.5 | 1 | 2.6 | 2.8 | −0.4 | 0.5 | 98.2 | 98.3
10 | 500 | 1.5 | 1.5 | 2.6 | 2.6 | −0.3 | −0.2 | 98.3 | 98.1
20 | 50 | 1 | 1 | 13.5 | 13.6 | −0.3 | 0.7 | 98.1 | 97.7
20 | 50 | 1 | 1.5 | 13.5 | 12.5 | −0.7 | −9.4 | 97.9 | 97.6
20 | 50 | 1.5 | 1 | 12.7 | 13.3 | −10.9 | 0.4 | 97.4 | 98.0
20 | 50 | 1.5 | 1.5 | 12.3 | 12.4 | −7.1 | −6.7 | 97.8 | 97.6
20 | 100 | 1 | 1 | 7.0 | 7.1 | 0.0 | −1.4 | 97.4 | 97.4
20 | 100 | 1 | 1.5 | 7.1 | 6.3 | 1.0 | −3.0 | 97.3 | 97.4
20 | 100 | 1.5 | 1 | 6.4 | 7.1 | −3.6 | 1.6 | 97.3 | 97.3
20 | 100 | 1.5 | 1.5 | 6.3 | 6.3 | −2.3 | −2.0 | 97.3 | 97.3
20 | 500 | 1 | 1 | 1.4 | 1.4 | 0.1 | −0.1 | 97.3 | 97.2
20 | 500 | 1 | 1.5 | 1.4 | 1.3 | 0.8 | −0.6 | 97.0 | 97.3
20 | 500 | 1.5 | 1 | 1.3 | 1.4 | −0.4 | 0.3 | 97.3 | 97.1
20 | 500 | 1.5 | 1.5 | 1.3 | 1.3 | −0.6 | −0.2 | 97.0 | 96.9

Appendix Table 8 MSE, coverage and bias for random effects univariate meta-analysis averaging over K, N, θ_1_ and θ_2_

τ_1_^2^ | τ_2_^2^ | ρ | MSE for θ̂_1_ (×10^−3^) | MSE for θ̂_2_ (×10^−3^) | Bias for θ̂_1_ (×10^−3^) | Bias for θ̂_2_ (×10^−3^) | Coverage (%) for θ̂_1_ | Coverage (%) for θ̂_2_
0 | 0 | −0.8 | 10.4 | 10.2 | −2.1 | −0.2 | 98.0 | 97.8
0 | 0 | −0.5 | 10.3 | 10.8 | −2.5 | −2.1 | 98.0 | 98.0
0 | 0 | −0.2 | 10.7 | 10.5 | −1.2 | −2.4 | 97.9 | 97.8
0 | 0.1 | −0.8 | 10.4 | 10.8 | −2.0 | −2.4 | 98.2 | 97.7
0 | 0.1 | −0.5 | 10.7 | 10.4 | −0.8 | −0.9 | 97.9 | 98.1
0 | 0.1 | −0.2 | 10.5 | 10.7 | −2.0 | −3.2 | 97.9 | 97.9
0 | 0.5 | −0.8 | 10.7 | 10.8 | −0.5 | −0.6 | 97.9 | 97.9
0 | 0.5 | −0.5 | 10.5 | 10.7 | −1.6 | −2.2 | 98.0 | 98.0
0 | 0.5 | −0.2 | 10.6 | 10.5 | −2.0 | −1.8 | 98.0 | 98.1
0.1 | 0 | −0.8 | 10.6 | 10.7 | −2.5 | −1.6 | 98.1 | 97.8
0.1 | 0 | −0.5 | 10.5 | 10.6 | −3.0 | −0.6 | 98.0 | 98.0
0.1 | 0 | −0.2 | 10.6 | 10.5 | −1.3 | −2.7 | 97.8 | 97.8
0.1 | 0.1 | −0.8 | 10.7 | 10.3 | −2.3 | −1.4 | 97.8 | 97.9
0.1 | 0.1 | −0.5 | 10.4 | 10.9 | −3.1 | −1.7 | 98.0 | 97.7
0.1 | 0.1 | −0.2 | 10.5 | 10.6 | −0.2 | −1.9 | 98.1 | 97.9
0.1 | 0.5 | −0.8 | 10.9 | 10.9 | −1.9 | −3.3 | 97.8 | 97.8
0.1 | 0.5 | −0.5 | 10.5 | 10.6 | −0.4 | −3.3 | 97.9 | 97.9
0.1 | 0.5 | −0.2 | 10.8 | 10.9 | −2.2 | −0.6 | 97.9 | 97.9
0.5 | 0 | −0.8 | 10.6 | 10.6 | −3.5 | −0.9 | 97.8 | 98.0
0.5 | 0 | −0.5 | 10.5 | 10.9 | −0.6 | −1.8 | 97.9 | 97.9
0.5 | 0 | −0.2 | 10.4 | 10.5 | −0.9 | −1.8 | 97.8 | 98.0
0.5 | 0.1 | −0.8 | 10.7 | 10.3 | 0.5 | −2.4 | 97.9 | 98.1
0.5 | 0.1 | −0.5 | 11.0 | 10.5 | −1.9 | −1.3 | 98.0 | 98.2
0.5 | 0.1 | −0.2 | 10.7 | 10.4 | −2.0 | −1.7 | 97.9 | 98.2
0.5 | 0.5 | −0.8 | 10.8 | 10.6 | −2.4 | −0.9 | 97.9 | 97.8
0.5 | 0.5 | −0.5 | 10.6 | 10.6 | −1.7 | 0.2 | 98.1 | 98.0
0.5 | 0.5 | −0.2 | 10.7 | 10.2 | −3.1 | −0.8 | 97.9 | 98.2

## References

1 Lu G, Ades A. Modeling between-trial variance structure in mixed treatment comparisons. Biostatistics. Oct. 2009;10(4):792-805. [pmid: 19687150].
2 Pinheiro JC, Bates DM. Unconstrained parameterizations for variance-covariance matrices. Stat Computing. 1996;6:289-96.