# References

1 Witte S, Victor N. Some problems with the investigation of noninferiority in meta-analysis. Methods Inf Med. 2004;43(5):470-4. [pmid: 15702203].
2 Lange S, Biester K. The equivalence of non-inferiority problem in systematic reviews. [abstract P172]. XIII Cochrane colloquium. 2005 Oct 22–26. Melbourne, Australia. 2005.
3 Prins H, de Haan R. Formal criteria for establishing equivalence in meta-analysis of randomized clinical trials. [abstract PB34]. 8th international Cochrane colloquium. 2000. Cape Town, South Africa. 2000.
4 ICH Expert Working Group. ICH harmonised tripartite guideline: statistical principles for clinical trials. Geneva. International Conference on Harmonisation. Feb. 5. 1998:39. www.ich.org/fileadmin/Public_Web_Site/ICH_Products/Guidelines/Efficacy/E9/Step4/E9_Guideline.pdf.
5 Committee for Proprietary Medicinal Products (CPMP). ICH topic E 10: choice of control group in clinical trials. London, UK. European Medicines Agency. January. 2001:30.
6 Committee for Proprietary Medicinal Products (CPMP). Points to consider on switching between superiority and non-inferiority. London, UK. European Medicines Agency. July. 27. 2000:11. www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003658.pdf.
7 Committee for Proprietary Medicinal Products (CPMP). Note for guidance on the investigation of bioavailability and bioequivalence. London, UK. European Medicines Agency. December. 14. 2000:19.
8 Committee for Proprietary Medicinal Products. Common technical document for the registration of pharmaceuticals for human use, Clinical overview and clinical summary of module 2. Module 5: study reports. London, UK. European Medicines Agency. July. 2003:44. www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500002723.pdf.
9 Committee for Proprietary Medicinal Products (CPMP). Guideline on the choice of the non-inferiority margin. London, UK. European Medicines Agency. July. 27. 2005:11. www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003636.pdf.
10 Pharmaceutical Benefits Advisory Committee. Guidelines for preparing submissions to the Pharmaceutical Benefits Advisory Committee (Version 4.3). Barton ACT. Commonwealth of Australia. December. 2008:300. www.pbs.gov.au/industry/listing/elements/pbac-guidelines/PBAC4.3.2.pdf.
11 Points to be considered by the review staff involved in the evaluation process of new drug. Final. Tokyo, Japan. Pharmaceuticals and Medical Devices Agency (PMDA). April. 17. 2008:6. www.pmda.go.jp/english/service/pdf/points.pdf.
12 Center for Drug Evaluation and Research, Center for Biologics Evaluation and Research. Guidance for industry: non-inferiority clinical trials [draft guidance]. Rockville, MD. U.S. Food and Drug Administration. March. 2010:66. www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM202140.pdf.
13 Guidance for industry on preparation of common technical document for import / manufacture and marketing approval of new drugs for human use (New Drug Application – NDA). New Delhi. Central Drugs Standard Control Organization. November. 2010:110. http://cdsco.nic.in/CTD_Guidance%20-Final.pdf.
14 Gomberg-Maitland M, Frison L, Halperin JL. Active-control clinical trials to establish equivalence or noninferiority: methodological and statistical concepts linked to quality. Am Heart J. Sep. 2003;146(3):398-403. [pmid: 12947355].
15 Piaggio G, Elbourne DR, Altman DG, et al. Reporting of noninferiority and equivalence randomized trials: an extension of the CONSORT statement. JAMA. Mar. 8. 2006;295(10):1152-60. [pmid: 16522836].
16 Guidance for industry: statistical approaches to establishing bioequivalence. Rockville, MD. U.S. Department of Health and Human Services, Food and Drug Administration, Center for Drug Evaluation and Research. January. 2001:48. www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/ucm070244.pdf.
17 Aujensky D, Roy PM, Verschuren F, et al. Outpatient versus inpatient treatment for patients with acute pulmonary embolism: an international, open-label, randomised, non-inferiority trial. Lancet. Jul. 2. 2011;378(9785):41-8. [pmid: 21703676].
18 Matilde Sanchez M, Chen X. Choosing the analysis population in non-inferiority studies: per protocol or intent-to-treat. Stat Med. Apr. 15. 2006;25(7):1169-81. http://rds.epi-ucsf.org/ticr/syllabus/courses/26/2007/01/23/Other/readings/ITT%20vs%20PP%20non-inf%20trials.pdf. [pmid: 16397861].
19 Assessing the risk of bias of individual studies when comparing medical interventions. Rockville, MD. Agency for Healthcare Research and Quality. June. 9. 2011:30. www.effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?productid=714&pageaction=displayproduct.
20 Treadwell JR. Methods project 1: existing guidance for individual trials. Plymouth Meeting, PA. ECRI Institute. June. 29. 2011:39.
21 Wangge G, Klungel OH, Roes KC, et al. Room for improvement in conducting and reporting non-inferiority randomized controlled trials on drugs: a systematic review. PLoS ONE. 2010;5(10):e13550. www.ncbi.nlm.nih.gov/pmc/articles/PMC2965079. [pmid: 21048948].
22 Scott IA. Non-inferiority trials: determining whether alternative treatments are good enough. Med J Aust. Mar. 16. 2009;190(6):326-30. www.mja.com.au/public/issues/190_06_160309/sco10995_fm.html. [pmid: 19296815].
23 D’Agostino RB Sr, Massaro JM, Sullivan LM. Non-inferiority trials: design concepts and issues—the encounters of academic consultants in statistics. Stat Med. Jan. 2003;22(2):169-86. [pmid: 12520555].
24 Sutter S. FDA panel to consider rivaroxaban’s comparative efficacy. Family practice news [database online]. Rockville, MD. International Medical News Group, LLC. Sep. 7. 2011:4. www.familypracticenews.com/index.php?id=2934&type=98&tx_ttnews[tt_news]=62576&cHash=da03e20e36. Accessed September 8, 2011.
25 Patel MR, Mahaffey KW, Garg J, et al. Rivaroxaban versus warfarin in nonvalvular atrial fibrillation. N Engl J Med. www.nejm.org/doi/pdf/10.1056/NEJMoa1009638. 2011;365:1557-9. [pmid: 21992495].
26 Morrissey JP, Dalton KM, Steadman HJ, et al. Assessing gaps between policy and practice in Medicaid disenrollment of jail detainees with severe mental illness. Psychiatr Serv. Jun. 2006;57(6):803-8. [pmid: 16754756].
27 Schunemann HJ, Guyatt GH. Commentary--goodbye M(C)ID! Hello MID, where do you come from?. Health Serv Res. Apr. 2005;40(2):593-7. www.ncbi.nlm.nih.gov/pmc/articles/PMC1361157/pdf/hesr_00374.pdf. [pmid: 15762909].
28 Lemieux J, Beaton DE, Hogg-Johnson S, et al. Three methods for minimally important difference: no relationship was found with the net proportion of patients improving. J Clin Epidemiol. May. 2007;60(5):448-55. www.sciencedirect.com/science?_ob=MImg&_imagekey=B6T84-4MJC1Y5-7-5&_cdi=5076&_user=851995&_pii=S0895435606003234&_origin=&_coverDate=05/31/2007&_sk=999399994&view=c&wchp=dGLzVzz-zSkWB&_valck=1&md5=944e41c59e1e716b5d451a64b1bed015&ie=/sdarticle. [pmid: 17419955].
29 Troosters T. How important is a minimal difference. Eur Respir J. Apr. 2011;37(4):755-6. http://erj.ersjournals.com/content/37/4/755.full.pdf. [pmid: 21454895].
30 Dworkin RH, Turk DC, Wyrwich KW, et al. Interpreting the clinical importance of treatment outcomes in chronic pain clinical trials: IMMPACT recommendations. J Pain. Feb. 2008;9(2):105-21. [pmid: 18055266].
31 Committee for medicinal products for human use (CHMP) guideline on the choice of the non-inferiority margin. Stat Med. May. 30. 2006;25(10):1628-38. [pmid: 16639773].
32 Hagg O, Fritzell P, Nordwall A, et al. The clinical importance of changes in outcome scores after treatment for chronic low back pain. Eur Spine J. Feb. 2003;12(1):12-20. [pmid: 12592542].
33 Cohen J. Statistical power analysis for the behavioral sciences. 2nd ed. Hillsdale, NJ. Lawrence Erlbaum Associates. 1988:567.
34 ICH Expert Working Group. ICH Harmonized Tripartite Guideline: choice of control group and related issues in clinical trials E10. July. 20. 2000:35. www.sourcesolution.com/speakup/resources/download/E10-_Choice_of_Control_Group_and_Related_Issues_in_Clinical_Trials.pdf. Accessed March 16, 2012.
35 Wells G, Beaton D, Shea B, et al. Minimal clinically important differences: review of methods. J Rheumatol. Feb. 2001;28(2):406-12. [pmid: 11246688].
36 Beninato M, Gill-Body KM, Salles S, et al. Determination of the minimal clinically important difference in the FIM instrument in patients with stroke. Arch Phys Med Rehabil. Jan. 2006;87(1):32-9. [pmid: 16401435].
37 Garattini S, Bertele’ V. Ethics in clinical research. J Hepatol. Oct. 2009;51(4):792-7. [pmid: 19664839].
38 Gentile I, Borgia G. Surrogate endpoints and non-inferiority trials in chronic viral hepatitis. J Hepatol. May. 2010;52(5):778. [pmid: 20347500].
39 Siegel JP. Equivalence and noninferiority trials. Am Heart J. Apr. 2000;139(4):S166-70. [pmid: 10740125].
40 Revicki D, Hays RD, Cella D, et al. Recommended methods for determining responsiveness and minimally important differences for patient-reported outcomes. J Clin Epidemiol. Feb. 2008;61(2):102-9. [pmid: 18177782].
41 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions—Agency for Healthcare Research and Quality and the Effective Health Care Program. J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
42 Stettler C, Wandel S, Allemann S, et al. Outcomes associated with drug-eluting and bare-metal stents: a collaborative network meta-analysis. Lancet. Sep. 15. 2007;370(9591):937-48. [pmid: 17869634].
43 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the effective health care program. J Clin Epidemiol. Nov. 2011;64(11):1187-97. Epub 2011 Apr 7. [pmid: 21477993].
44 Fu R, Gartlehner G, Grant M, et al. Conducting quantitative synthesis when comparing medical interventions: AHRQ and the Effective Health Care Program. Methods Guide for Comparative Effectiveness Reviews. Rockville, MD. Agency for Healthcare Research and Quality. October. 2010:25. http://effectivehealthcare.ahrq.gov.
45 Meier P, Baker P, Jost D, et al. Chest compressions before defibrillation for out-of-hospital cardiac arrest: a meta-analysis of randomized controlled clinical trials. BMC Med. 2010;8:52. [pmid: 20828395].
46 O’Hagan L, Luce BR. A primer on Bayesian statistics in health economics and outcomes research. Bethesda, MD. MEDTAP International, Inc. 2003:72. www.shef.ac.uk/content/1/c6/02/55/92/primer.pdf.
47 Quilici S, Abrams KR, Nicolas A, et al. Meta-analysis of the efficacy and tolerability of pramipexole versus ropinirole in the treatment of restless legs syndrome. Sleep Med. Oct. 2008;9(7):715-26. [pmid: 18226947].
48 Furukawa TA, Barbui C, Cipriani A, et al. Imputing missing standard deviations in meta-analyses can provide accurate results. J Clin Epidemiol. Jan. 2006;59(1):7-10. [pmid: 16360555].
49 Thiessen Philbrook H, Barrowman N, Garg AX. Imputing variance estimates do not alter the conclusions of a meta-analysis with continuous outcomes: a case study of changes in renal function after living kidney donation. J Clin Epidemiol. Mar. 2007;60(3):228-40. [pmid: 17292016].
50 Bingham CO 3rd, Sebba AI, Rubin BR, et al. Efficacy and safety of etoricoxib 30 mg and celecoxib 200 mg in the treatment of osteoarthritis in two identically designed, randomized, placebo-controlled, non-inferiority studies. Rheumatology (Oxford). Mar. 2007;46(3):496-507. http://rheumatology.oxfordjournals.org/content/46/3/496.full.pdf. [pmid: 16936327].
51 ECRI Institute. Inhaled insulin for type 1 diabetes, ECRI Institute evidence report No. 149. Plymouth Meeting, PA. ECRI Institute Health Technology Assessment Information Service. September. 2007:147.
52 ECRI Institute. Inhaled insulin for the treatment of type 2 diabetes, Windows on Medical Technology No. 146. Plymouth Meeting, PA. ECRI Institute Health Technology Assessment Information Service. June. 1. 2007:141. http://www.ecri.org.
53 Weng TC, Yang YH, Lin SJ, et al. A systematic review and meta-analysis on the therapeutic equivalence of statins. J Clin Pharm Ther. Apr. 2010;35(2):139-51. [pmid: 20456733].
54 Beauchamp MK, Nonoyama M, Goldstein RS, et al. Interval versus continuous training in individuals with chronic obstructive pulmonary disease—a systematic review. Thorax. Feb. 2010;65(2):157-64. [pmid: 19996334].
55 Eyawo O, Nachega J, Lefebvre P, et al. Efficacy and safety of prostaglandin analogues in patients with predominantly primary open-angle glaucoma or ocular hypertension: a meta-analysis. Clin Ophthalmol. 2009;3:447-56. [pmid: 19684868].