# Methods

## Workgroup Composition

The workgroup for this chapter included 13 individuals from seven EPCs and AHRQ. All members of the workgroup had specifically expressed interest in working on the guidance, and many had prior expertise in the analysis and interpretation of equivalence and noninferiority trials. The project was led by the ECRI Institute EPC. Project leadership involved setting the scope and timeline, scheduling conference calls, devising and assigning subgroups, participating in all subgroups, contributing to the writing of sections of the draft guidance chapter, assembling documents for groupwide review, and writing the first drafts of the Introduction and Methods sections.

## Methods Projects

Prior to developing any guidance, the lead EPC also performed two methods projects intended to assist the workgroup in clarifying the context, prioritizing the issues, targeting the scope, and summarizing the state-of-the-art. The first project involved a review of 12 existing guidance documents (identified by a medical librarian using a targeted literature search) pertaining to equivalence and noninferiority (see Appendix B, Methods Project 1). These guidance documents (10 from regulatory agencies and 2 from academia) were all intended for primary researchers designing and interpreting equivalence trials. Major insights from this project (according to the author of the project) were:

- EQ-NI trials are conducted in many contexts, such as (1) placebo-controlled trials are unethical because a proven treatment exists, (2) the advantage of the test intervention (e.g., safety, cost, and/or convenience) may counterbalance the reduced efficacy, or (3) there is a general interest in comparative efficacy or effectiveness.
- The guidance unanimously emphasized a priori specification of the decision threshold.
- The guidance also emphasized that researchers should justify the chosen threshold.
- The guidance was unclear on how researchers should determine the threshold. The documents suggested a focus on “clinical” impact, but the specific meaning of this was unclear. The guidance suggested researchers should also consider statistical considerations, how well the active comparator works, historical data, safety, cost, acceptability, adherence, independent expert consensus, and regulatory requirements.
- Regarding risk of bias, the documents mentioned nine areas that can contribute to underestimates of the difference between active treatments. Most of these areas can also contribute to overestimates, depending on the specifics of the situation (this point about overestimation was not made by the regulatory documents, but rather by the author of Methods Project 1).
- The concerns of regulatory agencies are different from those of systematic reviewers. For example, systematic reviewers are concerned about any direction of bias, whereas regulatory agencies are primarily concerned about bias in favor of the sponsor’s product. Also, regulatory agencies generally assume that a trial should stand on its own to demonstrate a finding, whereas systematic reviewers view a trial as one in a larger set of trials that, taken together, may or may not demonstrate a consistent finding.

The second methods project involved assessing methodology used within 50 recent systematic reviews that contain conclusions that could be interpreted as conclusions of EQ-NI between two or more treatments (see Appendix C, Methods Project 2). The reviews were randomly selected from 235 reviews identified in a targeted literature search by a medical librarian. This project focused on methodology related to the following areas within systematic reviews: assessing risk of bias, defining the minimum important difference (MID), analytical basis for drawing conclusions of EQ-NI, and wording of conclusions of EQ-NI. Major insights from this project (according to the authors of the project) were:

- Authors of reviews rarely address how risk of bias factors known to impact studies of EQ or NI differently than studies of superiority will be assessed and taken into account when drawing conclusions of EQ-NI.
- Authors of reviews rarely define or use a decision threshold such as a MID.
- Authors of reviews rarely prespecify how they will handle findings of no difference or similarity. In many of the reviews assessed, meta-analytic findings of no statistically significant difference were simply interpreted as demonstrating equivalence, without any mention of whether an MID was employed in the process.
- Authors of reviews typically use indirect language (e.g., “There is no evidence that [video assisted thoracoscopic surgery] VATs is more effective than fibrinolytic treatment.”) to express conclusions of EQ-NI instead of using more direct terms, such as “equivalent to,” “similar to,” “comparable to,” and “not inferior to” to express conclusions of EQ-NI.

## Guidance Development

We split the workgroup into four subgroups, each assigned to a specific section of the guidance. Each workgroup member participated in one or more subgroups. The subgroups were:

- Unique risk of bias issues for trials self-identifying as EQ-NI trials.
- Setting the reviewer’s Minimum Important Difference (MID).
- Analytic foundations for concluding EQ or NI.
- Language considerations when concluding EQ or NI.

Each subgroup devised guidance on their topic based on telephone and email communications. Given the lack of empirical guidance, the recommendations were opinion-based, and were informed by the two Methods projects described above as well as the previous experience and knowledge of the workgroup members.

A first draft of a combined guidance document (containing all four sections) was reviewed by the full workgroup. Based on comments and suggestions received, the lead EPC made revisions to the combined document. The document was posted for public comment for one month (November 2011), and five public commenters provided feedback. In addition, we relied on seven solicited peer reviewers with expertise in systematic review (e.g., EPC directors and associate directors) and/or equivalence/noninferiority trials (e.g., an EPC statistician, and an FDA statistician). Further, the AHRQ Task Order Office and associate editor provided additional comments and feedback. Two workgroup calls near the end of the project were used to clarify responses to the major comments received. Overall, the reviews resulted in numerous edits, additions, and clarifications.