# Guidance

## Section 1 Unique Risk of Bias Issues for Trials Self-Identifying as EQ-NI

In this section, we consider the unique aspects of risk of bias that require particular attention when assessing trials that define themselves as EQ-NI trials. According to Sanchez and Chen, EQ-NI trials “are not conservative in nature.”18 In other words, EQ-NI trials are vulnerable to certain biases that require systematic reviewers to pay particular attention to the direction of potential biases. Specifically, an “equivalence trial” may have been conducted in ways (intentionally or unintentionally) that underestimated the difference between treatments. Or, a “noninferiority trial” comparing a new treatment to an established treatment may have been conducted in ways (intentionally or unintentionally) that tended to bias results in favor of the new treatment.

Like superiority trials, the sources of bias in EQ-NI trials commonly include selection, performance, detection, and attrition bias.19 In the first methods project to inform this guidance, Treadwell highlighted several risk of bias issues that are of concern to EQ/NI trials.20 Many of these issues are also of concern in superiority trials. However, their impact on the results of a trial is likely to differ between superiority and EQ-NI trails. The issues include poorly implemented entry criteria, poor adherence, concomitant treatments, protocol violations, and inadequate measurement techniques. In Table 1, we list the risk of bias issues reported in Treadwell’s review and briefly summarize the implications of these issues on the findings of EQ-NI trials (e.g., whether the bias would tend to lead to underestimates or overestimates of the difference between groups). We also present questions that reviewers might want to consider when assessing EQ-NI trials to detect bias.

Table 1 Issues related to risk of bias in EQ-NI trials

Source of Bias | Risk of Bias Issue | Implication on Findings of Equivalence/Noninferiority Trials | Question To Identify Bias
Selection | Inconsistent application of inclusion/exclusion criteria | When inclusion criteria are inconsistently applied across intervention and comparator arms, the study may be biased toward an under-or overestimate of the difference between groups because patients in the treatment groups may vary in ways that impact response to treatment. | Were the inclusion/exclusion criteria clearly stated and implemented consistently across all study participants?
Selection | Patients selected for anticipated nonresponse or good response in one arm | If patients are selectively recruited for anticipated response in one arm, the study may make a treatment seem significantly worse or better than the other. | Were participants selected for nonresponse or positive response?
Performance | Poor adherence | If adherence is poor within both treatment groups, the difference between groups would be underestimated. If adherence varies by treatment group, the difference between groups may be overestimated. | Was adherence with treatment sufficient in both of the study’s groups and across all subgroups?
Performance | Use of concomitant treatments | Use of concomitant treatments by both treatment groups can mask the difference between groups and lead to an underestimate of the difference. Use of concomitant treatment more often in one treatment group than the other can lead to an overestimate of the difference. | Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias or confound results?
Performance | Protocol violations | Any deviation from the study protocol (e.g., intended treatment regimen, schedule, and manner measuring outcomes, etc.) can reduce the sensitivity of a trial and lead to an underestimate of the difference between groups and a higher likelihood of a conclusion of EQ-NI. | Did the study vary from the protocol in treatment assignments? Did researchers deliver the assigned treatment appropriately in terms of dose, schedule, and duration?
Detection | Inadequate outcome measurement techniques | Use of nonvalid instruments or improper use of valid instruments to measure outcomes could lead to an underestimate or overestimate of the difference between groups. Use of a data collection method/mode that can influence the likelihood of outcome could mute or lead to an underestimate of the difference. | Was the outcome measured using a validated instrument? Was the outcome measure of interest objective and was it objectively measured? Was the outcome measure properly administered (e.g., interviewers properly trained on interview protocol)?
Detection | Lack of blinding outcomes assessor | Outcome assessors may be biased (consciously or unconsciously) toward finding no difference if they know that all groups received active treatment. | Were those who assessed the patient’s outcomes blinded to the group to which patients were assigned?
Attrition | Drop out, loss to followup | Intention-to-treat (ITT) analysis may underestimate the difference. Study should present both ITT and results with dropouts excluded (or per protocol analysis). | Was there a high rate of differential or overall attrition? Were intention-to-treat and per-protocol analyses used and reported?

When assessing the validity of the results of EQ-NI trials, it is important to keep in mind the assumption of the null hypothesis for these trials. Unlike superiority trials in which the null hypothesis assumes no difference between treatment arms, the null hypothesis in EQ-NI trials assumes a difference between arms.15 The difference in the nature of the null hypothesis between superiority trials and EQ-NI trials has an impact on what sources of bias are more or less relevant for reviewers to consider. A conservative approach to evaluating the null hypothesis in a superiority trial requires paying attention to sources of bias that may artificially inflate the differences between study arms. A similarly conservative approach to evaluating the null hypothesis for EQ-NI trials requires paying close attention to sources of bias that may artificially reduce the differences between study arms.

The guidance in this section refers primarily to risk of bias when assessing RCTs. Observational studies can also test assertions of EQ/NI; evaluation of risk of bias from such studies would need to account for confounding and other selection biases in addition to the biases listed below. When assessing EQ-NI trials, reviewers should keep in mind the following issues related to selection, performance, detection, and attrition that make EQ-NI trials especially vulnerable to bias. These sources of bias are applicable to superiority trials as well. Table 1 describes their application to EQ/NI trials.

### Selection

#### Application of Inclusion/Exclusion Criteria

As indicated in Table 1, inclusion/exclusion criteria that are inconsistently applied across intervention and comparator arms may bias the study toward an under- or overestimate of the difference between groups. This is because inconsistent application of inclusion/exclusion criteria may result in differences between patients that can impact their response to treatment.

### Performance

#### Protocol Violations

In EQ-NI trials, deviations from the inclusion criteria, from the intended treatment regimen, from the schedule, and from the manner and precision of measuring outcomes can reduce the sensitivity of a trial to detect real differences. This has the potential to underestimate the different between treatments, even in situations where the deviations are of an unsystematic or random nature.6 Thus, reviewers need to assess these trials carefully for any violations in the intended protocol.

#### Treatment Adherence

EQ-NI trials require a high degree of patient adherence to treatment in both the new and active comparator groups. For instance, use of concomitant medications in both groups can produce a ceiling effect that can mask differences between the two treatments.14 Use of concomitant medication more often in one group than the other can bias the trial toward finding a favorable difference for one treatment over the other.

### Detection

#### Blinding

Wangge et al. suggest that in a superiority trial, a blinded outcome assessor who has a preliminary belief in the superiority of the one of the treatments is unable (due to blinding) to manipulate the results to support his/her belief. Not knowing the treatment status of the patients in a superiority trial prevents the outcome assessor from assigning more positive ratings to one group of patients. In EQ-NI trials, however, the value of blinding outcome assessors is debatable, especially if the end points are subjective.21 In an EQ-NI trial, the blinded outcome assessor with a preliminary belief in equivalence or noninferiority of the test intervention can still bias the results by assigning similar ratings to the treatment response of all patients.

#### Duration of Treatment and Evaluations

In EQ-NI trials, the randomized treatments need to be given for long enough and the patient response evaluated over a long enough period so that any potential treatment differences have a realistic opportunity to reveal themselves.22 Conversely, researchers may not have measured short-term outcomes that would have shown a difference (e.g., short-term pain after laparoscopic surgery vs. open surgery). Thus reviewers should pay particular attention to these factors in EQ-NI trials, and use the duration of treatment and length of followup in previous trials demonstrating efficacy of the active comparator as a reference (assuming the same outcome measures were used in those previous trials). In addition, reviewers can consult the general literature on the appropriate measuring timing for those outcomes.

### Attrition

#### Intention-to-Treat Analysis (ITT)

An ITT analysis includes all participants according to the treatment to which they have been randomized, even if they do not receive the treatment. Protocol violators, patients who miss one or more visits, patients who drop out, and patients who were randomized into the wrong group are analyzed according to the planned treatment. In superiority trials, the ITT approach is considered the most appropriate approach because it tends to avoid overly optimistic estimates of treatment efficacy (noncompleters included in the analysis will generally diminish the estimated treatment effect).18 In EQ-NI trials, however, the ITT approach does not have the same conservative effect. Use of an ITT analysis in these trials could lead to a false conclusion of EQ-NI by diluting any real treatment differences.

In EQ-NI trials, a per-protocol analysis, which considers outcomes only among patients who complete the trial, may be more appropriate than it is in superiority trials.12 However, according to Sanchez and Chen, this analytical approach is not without problems as completers are a select group of patients who may bias the trial in favor of one treatment over the other.18 These and other authors suggest that EQ-NI trials include both ITT and per-protocol approaches as there is no single ideal approach in situations where there is substantial non-adherence or missing data. We recommend that systematic reviewers consider both per-protocol and intention-to-treat analyses, and also evaluate reasons for drop-out, as a means for understanding the potential for bias, especially if one of the treatments is more toxic than the other.

### Similarity of EQ-NI Trials to Trials That Established Efficacy of the Active Comparator

EQ-NI trials rely on two assumptions: assay sensitivity and constancy. Assay sensitivity assumes that the superiority of the active control over placebo has been established and will be preserved under the conditions of the EQ-NI trial.12 Constancy assumes that a EQ-NI trial is sufficiently similar to previous trials that showed the superior efficacy of the active comparator to placebo.23 These assumptions, together with a supportive finding in an EQ-NI trial, can permit the indirect inference that the new treatment works, in the absence of direct placebo-controlled trials of that new treatment.

Thus, an EQ-NI trial should not only be assessed for factors that might obscure differences between treatments, but also for factors that might make the trial different from the trials that demonstrated efficacy of the active comparator.5 When assessing the validity of EQ-NI trials, reviewers should therefore determine if the participants and outcomes are similar to those in trials that established efficacy of the active comparator versus placebo. If patients in an EQ-NI trial deviate in ways that may affect their response to treatment from the patients in trials that demonstrated superiority of the active treatment control, then any claim about the efficacy of the new treatment could not be distinguished between true EQ-NI and inappropriate selection of patients. Similarly, outcome measures (and the timing of measurement) used in EQ-NI trials should be similar to those used in trials to demonstrate superiority of the active comparator in order to appropriately conclude EQ-NI. Finally, the active comparator in EQ-NI trials should be given in the same form, dose, and quality as was previously used to demonstrate the efficacy of that treatment over placebo. Presence of a distinct difference in these characteristics may decrease the strength of inference. One subtle possibility concerns the development of antibiotic resistance; an active comparator may be less efficacious than it used to be due to a fundamental change in the disease being treated.

Typically, EQ-NI trials do not include a comparison of the test treatment with placebo. In a systematic review, however, both treatments may have been compared to the placebo, and the choice of test treatment versus active comparator may sometimes depend on the framing of the research question. Demonstrating the superiority of both treatments over placebo may strengthen the inference of EQ/NI in the context of systematic review, and if two treatments are concluded to yield similar outcomes, the reviewer should determine that both treatments actually benefitted patients (see Section 3 of this guidance for other factors affecting this inference).

A recent example in which the claims of a NI trial were questioned is the ROCKET trial comparing the efficacy of the new anticoagulant medication, rivaroxaban, to the commonly used standard medication, warfarin.24,25 In their review of the trial for regulatory approval, the Food and Drug Administration (FDA) questioned the authors’ conclusion that rivaroxaban was noninferior to warfarin for the prevention of stroke or systemic embolism in patients with nonvalvular atrial fibrillation. The reviewers of the study expressed concern about the dosage of warfarin used in the ROCKET trial compared to doses used in other recently published warfarin-controlled trials. Specifically, FDA was concerned because the “mean time in therapeutic range (or TTR) in the warfarin arm was 55 percent, which is well below the TTR in other recent warfarin-controlled studies (63 percent to 73 percent).”26 Regulatory approval of rivaroxaban depends on further review by FDA.

To determine whether the conditions in an EQ-NI trial are similar to those in previous trials that demonstrated superiority of the active comparator, we recommend that reviewers consider the following questions suggested by Piaggio and colleagues:15

- Is the active comparator a well-established, effective standard therapy that has predictable and consistent treatment effects?
- Is the active comparator in the EQ-NI trial the same or very similar to that in trials that established its efficacy in terms of form, dose, and quality?
- Are participants in the EQ-NI trial the same or very similar to those in trials that established the efficacy of the active comparator?
- Are the outcomes in the EQ-NI trial the same or very similar to those in trials that established the efficacy of the active comparator?

The questions listed above are likely to be relevant at multiple stages in the review process and should be considered early during the development of the PICOTS (patients, interventions, controls, outcomes, timing, and settings) and inclusion/exclusion criteria. Interpreting answers to these questions requires clinical judgment, particularly when the response to one or more of the questions listed above is “no” or when comparators, participants, and outcomes are “very similar” but not the same as in the efficacy trials. Systematic reviews that make conclusions about EQ/NI (discussed in more detail in Section 3 of this guidance) have the responsibility to ensure that these conclusions build on evidence of the efficacy of the active comparator. This evidence may come from pre-existing reviews or the evidence may be generated at the same time as conclusions about EQ/NI as part of the same review.

Narrow and clear specification of inclusion/exclusion criteria may help to restrict the review to studies with PICOTS that are comparable to those in studies that established the efficacy of the active comparator. For more inclusive reviews, these questions will continue to be relevant and will need to be further considered when assessing the:

1. risk of bias of included studies (e.g., do deviations from the study protocol increase the risk of bias?);
2. the applicability of included studies (e.g., do populations, interventions, comparators, or outcomes that are not broadly generalizable reduce applicability?); and
3. the overall strength of evidence (e.g., does indirect or inconsistent evidence reduce the strength of evidence?).

Protocols for reviews that include EQ-NI studies should clarify when these questions will be addressed in the review process. Reviewers should also specify how included studies will be compared to placebo-controlled trials that established the efficacy of the active comparator (e.g., technical expert panel input, comparison with previous reviews of comparisons of the active comparator with placebo control).

### Completeness of Reporting

Assessing risk of bias of any study requires adequate reporting of the study.19 Standards for reporting are now available for EQ-NI trials. In 2006, Piaggio and colleagues extended the CONSORT (Consolidated Standards of Reporting Trials) statement and reporting checklist for randomized superiority trials to accommodate EQ-NI trials.15 The extension encompasses the following issues:

1. the rationale for adopting a noninferiority or equivalence design;
2. how study hypotheses were incorporated into the design;
3. choice of participants, interventions, and outcomes;
4. statistical methods; and
5. how the design affects interpretation and conclusions.

However, in a recent systematic review to identify how NI trials were conducted and reported, Wangge et al. found poor reporting.21 Only 3.0 percent of the 232 trials reviewed reported the similarity of the inclusion/exclusion criteria with previous trials on the effect of the active comparator, 5.6 percent of the trials reported the similarity of the type of intervention with previous trials, and 3.4 percent reported the similarity of outcomes. Further, the authors found no improvement of reporting after the release of the extension of the CONSORT statement for EQ-NI trials.

Thus, when assessing the risk of bias in study designs, we recommend that EPCs focus primarily on the design and conduct of studies and not on the quality of reporting.19 EPCs should set up clearly stated and consistent standards within their own reviews for how they will deal with the issue of poor reporting. Given the variety of possibilities, more specific guidance is difficult; making reviewer judgments transparent allows readers to evaluate the reasonableness of those judgments as well as the implications for the review.

## Section 2 Setting the Reviewer’s Minimum Important Difference

The aim of equivalence trials is to show that a new treatment is therapeutically similar to a standard treatment within a predefined margin of equivalence. Similarly, the aim of noninferiority trials is to show that a new treatment has at least as much efficacy as the standard treatment or is no worse by an amount less than a prespecified margin. Thus, conclusions of EQ-NI should be based on where the confidence interval for the treatment effect falls relative to the prespecified margin or value. Determining an appropriate margin or value is therefore extremely important within the context of a systematic review in which it is possible to draw a conclusion of EQ or NI.

In this guidance document, we use the term minimum important difference (MID) to refer to the selected margin or value of EQ-NI (sometimes referred to by others as Δ). Other terms, including minimal clinically important difference (MCID) and minimal clinically significant difference (MCSD) have also been used. Our concern with the word “clinically” is the possibility of shifting one’s focus away from the patient’s perspective; some users may interpret a “clinical” difference strictly from a clinician’s perspective or a policymaker’s perspective. Thus, we recommend the generic term MID, and we use the definition provided by Schunemann et al.: the smallest difference in score in the outcome of interest that informed what patients or proxies perceive as important, and which would lead the patient or clinician to consider a change in the management.27

### Ways To Determine MID

#### A Priori Versus Post-Protocol Specified MID

Having a prespecified MID not only helps to guide the interpretation of the findings of a systematic review, but also facilitates the evaluation of statistical significance in the context of clinical relevance.28 For instance, “a reviewer may identify a statistically significant difference between treatments, but this statistical difference may not inform clinicians or policy makers as to whether patients will perceive the [treatment] effects as a benefit or whether the effect is of any clinical relevance.”29

Determining an appropriate MID to use can be challenging. It might seem fitting to select a margin or value for the MID after the data have been extracted (post-protocol) for a systematic review. However, this process of selection (using knowledge about trial findings to inform the decision) can lead to or be viewed as a source of bias, and potentially decrease the validity of the review’s results and conclusions.

Members of ECRI Institute’s EPC are currently working on a comparative effectiveness review (CER) for the topic of inguinal hernia. After reviewing the included literature, it was apparent that the prespecified MID for the outcome measure of return to daily activities after surgery (a 7-day MID) to daily activities (because the typical time before returning to daily activities after surgery was only 10 days). Working with the project’s task order officer, the authors decided to change the MID (to 1 day instead of 7) for this outcome measure, provided justification for the new MID selection, and made a protocol amendment. Another example of a post-protocol MID selection or change includes the identification of an included trial’s validated MID that differed from the prespecified MID. In this example, a sensitivity analysis could be performed with the reviewer’s prespecified MID and the individual trial’s MID to determine if the results and potential conclusions differed on the outcome measure of interest.

The overall consensus from guidance documents and reviewers is that no overarching rule can be provided for determining MID for all clinical areas. Ideally, defining the MID a priori (during protocol development) and providing clinical and statistical justification for the selected value and/or margin is essential.9 The process of this determination will vary and will need to be tailored to the specific topic of interest. There are several ways for a systematic reviewer to determine an MID. Some processes may be more familiar to those involved with clinical trials vs. the overall assessment of a literature base. “Anchor-based methods for MID selection relate changes in scores on a measure to a standard that is different from the specific measure itself, whereas distribution-based methods use statistical parameters associated with the measure (e.g., effect size, standard error of measurement) to interpret the magnitude of changes in the measure’s scores over time.”30 The Delphi approach for defining MID may be used when systematic reviewers are assessing new treatments or treatments that are purported to improve patient-centered outcomes such as quality of life.

Another method that may be unfamiliar to the systematic review process has been recommended by FDA. For NI trials, FDA recommends “first determining the margin for the treatment effect of the active comparator (M1) and then calculate the margin for the test intervention (M2) by taking a percentage (e.g., 50 percent) of M1.”12 However, the European Medicines Agency (EMEA) recommended against this overall approach, stating: “It is not appropriate to define the [NI] margin as a proportion of the difference between active comparator and placebo. Such ideas were formulated with the aim of ensuring that the test product was superior to . . . placebo.”9 Systematic reviewers may acknowledge the MID that original trials aimed to examine, but justify the selection of a different MID and reevaluate the individual trial conclusions.

Reviewers should be careful when using the trials’ descriptions of statistical power as a basis for an MID. Some individual trial authors clearly state an MID when describing their power analyses (e.g., “For LDL, the minimum effect deemed important is seven percentage points”). However, other authors simply mention an effect size with their discussion of power, specifically an effect size they are looking for or an effect size they anticipate to occur. These are not necessarily MIDs. For example, if a study simply says that “our study had a 90 percent power to detect a standardized mean difference of 0.38,” that is not necessarily a statement about an MID, but rather an anticipated finding. The EMEA suggests that the choice of margin should be independent of considerations of power as the size of the clinically important difference is not altered by the size of the study.31

The following list provides suggested ways of determining and defining the MID. To strengthen the justification for MID selection—one or a combination of these suggestions may be used by systematic reviewers. Please note, this list is not exhaustive and reviewers may have other ways that are appropriate for the topic of interest:

- Use an already conducted empirical study. For example, one study calculated the minimal clinically important difference for the Oswestry Disability Index (ODI) and Visual Analog Scale (VAS) of back pain using linear regression analysis of score change compared to pretreatment scores.32 The authors determined that the minimal clinically important difference for the ODI was 10, and for the VAS of back pain it was 18–19.^32^
- Use a number suggested by a prominent authority and incorporated into trial’s design. For example, FDA has used 5 percent body weight loss as the definition of clinically significant weight loss. Also, FDA has defined therapeutic equivalence of plasma drug levels as the range from 80 percent to 125 percent.16
- FDA recommends first determining the margin for the treatment effect of the active comparator (M1) and then calculating the margin for the test intervention (M2) by taking a percentage (e.g., 50 percent of M1).12
- Use a number suggested by a clinical reviewer who is specialized in that clinical area. Such a reviewer may tailor their numerical recommendation to the specific clinical area.
- Use a number suggested by general reviewers, policy makers, public health professionals who are not specialized in that clinical area but are familiar with the outcome measure and the importance for individuals and public health.
- Use a number suggested by one or more of the studies being examined in the report, if a study asserts that the number is the minimum important difference or uses other such language. Some studies assert this in the methods section when describing their power analysis, but see further discussion of this point below.
- Use a number that was determined specifically for the review; one that ideally was derived from evidence based guidelines, literature reviews, or suggested by the review’s Technical Expert Panel or Key Informants.
- Use a number that was used in previous high-quality reviews examining this outcome measure.
- Use an MID based on Cohen’s book Statistical Power Analysis,33 which suggests definitions of small/moderate/large effects for different effect size metrics. For example, for the standardized mean difference, Cohen defined a small standardized mean difference as 0.2, moderate as 0.5, and large as 0.8.^28^
- Use anchor-based or distribution-based methods for determining or defining the MID for patient-reported outcome measures.

### MID for Specified Outcomes

Systematic reviewers are charged with the task of identifying an appropriate MID for one or more outcome measures of interest. For continuous outcomes, the idea is that very small differences (such as 1 point on a 0 to 100 scale) are negligible and can be ignored for the purposes of drawing a clear conclusion.

For dichotomous outcomes, however, the notion of an MID is more challenging. Any difference between treatment groups might seem to be important. For example, if the treatment under consideration is used for the prevention of death or irreversible morbidity and there is no second chance for treatment, even one additional event seems important, because it happened to one additional patient. However, if an infinitesimally small difference is still considered “important,” then an EQ-NI conclusion can never be reached, because one can never rule out the possibility of an “important” difference.

Systematic reviewers may be criticized for the MID value selected for dichotomous outcomes, especially if this value differs from previous systematic reviews. The selection may also be challenged when there is some uncertainty amongst reviewers, clinicians, experts; if no one has previously set the MID for the outcome; or if studies are using different MIDs for this outcome.

When uncertainty plays a role in MID selection, performing a sensitivity analysis can help systematic reviewers compare MID values and identify any changes in conclusions based on these values. Although it may be harder to defend the MID selection for dichotomous outcomes, not taking a stand is as problematic as the selection of some arbitrary MID. Without an MID, systematic reviewers may also draw unfounded conclusions.

Systematic reviewers will want to consider the importance of patient opinions about important difference in outcome measures (e.g., pain). Table 2 lists information for objectively measured vs. subjectively measured (e.g., patients self-reported) outcomes. “It is important to note that an important change in individual patients cannot be directly applied to the evaluation of clinically important group differences.”30 Also, systematic reviewers need to define the MID as the identified difference between treatment groups and not the changes in each group from baseline.5,30 The predefined margin quantifies the important difference between treatment groups, rather than the uncontrolled changes from baseline.34 In Appendix A, we included tables of MID examples that have been suggested or used for various clinical topics. These suggested MIDs may provide reviewers with a starting point as they develop the framework of the systematic review. As previously mentioned, the MID will typically vary depending on the topic assessed and reviewers should carefully determine and justify the chosen MID.

Table 2 Methods for identifying appropriate MID

Outcome | Method of Identifying Potential MID | Clinical Judgment of Importance of MID | Suggested Criteria To Use When Confirming MID Selection
Objectively measured | Continuous outcomes (mean difference)-literature review, guidelines, achieving consensus with several rounds of expert surveys using Delphi methods35 | Important for clinical management | Strong consistent association with mortality, morbidity, and/or quality of life36
Objectively measured | Continuous outcomes (mean difference)-literature review, guidelines, achieving consensus with several rounds of expert surveys using Delphi methods35 | Important for prognosis | Criteria of surrogate end points37,38
Objectively measured | Events data (relative risk, hazard ratio, odds ratio, absolute risk difference) - literature review, guidelines, achieving consensus with several rounds of expert surveys using Delphi methods35 | Magnitude of the effect (e.g., 25% relative difference or 25% absolute risk difference) Clinical importance of the effect (e.g., 100 attributable to active comparator prevented disability events per 1000 treated or 1.0% reduction in mortality39 | Identified based on low risk of bias efficacy placebo-controlled trials with target population similar for NI trial. Event rate with placebo established in efficacy trials should be taken into account Can be supported by dose response or active comparator studies Smallest number of the events should be prespecified
Subjectively measured (e.g., patient self-report) | Anchor method^*^ (preferable) - literature review, guidelines40 | Clinical anchors | Strong association (correlation) with importance for management or prognosis clinical outcomes
Subjectively measured (e.g., patient self-report) | Anchor method^*^ (preferable) - literature review, guidelines40 | Patient based anchors: perceived improvement in the disease, perceived improvement in quality of life, perceived treatment satisfaction | A single MID may be insufficient Consider several MIDs
Subjectively measured (e.g., patient self-report) | Achieving consensus with several rounds of expert surveys using Delphi methods)35 | Expert opinion about clinical importance of the difference in patient reported outcomes | Not applicable

* Anchor method compares patient opinion with scale score

EPCs should remain flexible in their approach to selecting the MID as multiple methods processes may be necessary. To adequately choose a MID for an outcome measure, an informed decision must be made, supported by evidence of what is considered an important difference in the particular disease area.31 Ultimately, the predetermined MID will help authors interpret the results and determine whether an EQ-NI conclusion is warranted. Piaggio et al. listed one required reporting item (item 7), that authors should specify the margin of equivalence as well as the rationale for its choice.15 EPCs should “clearly specify and demonstrate that a systematic approach has been taken in search for relevant and appropriate references to support the nominated threshold.”10

## Section 3 Analytic Foundations for Concluding EQ or NI

Conclusions of EQ-NI should be considered within the wider context of rating the strength-of-evidence (SOE) using the EPC guidance of Owens, et al.41 The SOE rating can be High, Moderate, Low or Insufficient. An Insufficient rating means that the evidence does not permit a conclusion. To arrive at a rating, four core domains (risk of bias, consistency, directness, and precision) as well as four optional domains (large magnitude of effect, publication bias, all-plausible-confounders-would-reduce-the-effect, and dose-response association) are considered. The rating can vary by outcome or by timepoint, because any of the underlying domains can vary accordingly (e.g., consistent data on one outcome but not another).

The sections below list numerous issues to be considered before concluding equivalence or noninferiority.

### Whether One Treatment Was Believed in Advance to be Better on Some Outcomes

As noted in the Introduction, this situation is a prerequisite for drawing a conclusion of noninferiority regarding an important effectiveness outcome. The typical situation is when test intervention is less costly, more convenient, or has fewer adverse effects, and potentially the clinical community would be willing to accept a small decrement in effectiveness in exchange for the known advantages. Thus, a conclusion that the test intervention is noninferior to the active comparator could apply. However, the reverse conclusion (that the active comparator is non-inferior to the test intervention) would not make sense.

If such prior knowledge on certain outcomes exists, the systematic reviewer should lay the groundwork for a possible conclusion of noninferiority by wording the Key Question accordingly. For example, the reviewer could phrase the Key Questions as: Is the efficacy of treatment A not lower than treatment B? Such wording reminds the user that the topic was approached a priori with a notion of noninferiority in a specific direction.

### Whether Trials Self-Identified as EQ-NI Trials

In the most straightforward circumstances, an EQ-NI conclusion can be drawn solely from trials describing themselves as EQ-NI trials. This may provide more reviewer confidence in the EQ-NI conclusion.

Often, however, studies do not self-identify as EQ-NI trials, and may even self-identify as superiority trials, and yet the accumulated evidence on one or more outcomes suggests equivalence. One example is the outcome of mortality when comparing bare metal stents and drug-eluting stents in the treatment of coronary artery disease. A systematic review published in 2007^42^ analyzed 17 trials, all of which were designed as superiority trials. Generally the trials did show superiority on the primary outcome of target lesion revascularization (evidence favoring drug-eluting stents), however the evidence on mortality led the reviewers to conclude equivalence (based on a summary hazard ratio of 1.03, 95% CI 0.84 to 1.22). Given the narrow confidence interval and the clear interpretation of the outcome, equivalence was a reasonable conclusion for mortality, even though the studies were designed as superiority trials. Overall, confidence in EQ-NI findings from superiority trials are enhanced if reviewers prespecify all critical components in their study protocol (e.g., the MID). If reviewers do so, the confidence in the subsequent decisions on the conclusions from the data need not depend on trial authors’ intentions to show EQ-NI. Reviewers should exercise their own independent judgments on EQ-NI.

Another question is whether to combine data from trials with a mix of author intentions: some trials self-identify as EQ, some as NI, some as superiority, and some do not specify. From the reviewer’s standpoint, the key concern is whether the various trials addressed the same Key Question. If studies enrolled similar patients, made the same treatment comparison, measured the same outcome in the same way at similar time points, then there is little reason not to consider the data together (either qualitatively or quantitatively), regardless of the trial authors’ intentions. Risk of bias, however, may be assessed differently based on author intentions (see Section 1 above).

In addition to author intent, what about reviewer intent? Reviewers should generally approach a Key Question without an a priori intent of what could or should be concluded. Instead, they should undertake a straightforward summary of the evidence. Thus, reviewers would generally not categorize their review as an “equivalence CER,” a “superiority CER,” or a “noninferiority CER.” Different outcomes could warrant different types of conclusions, depending on the data.

### Whether the Reviewer’s MID Was Prespecified and Justified by the Reviewer

The importance of prespecifying the MID was discussed above. The problem with post hoc specification involves the possibility of reviewer bias (whether intentional or unintentional). Specifically, a reviewer could set an MID that allows (or precludes) a conclusion of EQ or NI based on viewing the results of the studies. The same concern underlies the regulatory guidance statements that individual trial authors should prespecify their MIDs. A justification of the chosen MID is also important (also discussed above). If the MID is too large, an intervention could be claimed to be noninferior to an active comparator yet may actually have been clinically worse.

Some reviews may not have prespecified an MID, possibly because the review was initiated before this guidance was completed, or reviewers felt that any MID would be too uncertain. Such reviews may still be able to conclude equivalence or noninferiority for an outcome, but these conclusions would be based on a post-hoc MID or some unspecified MID in the mind of the reviewer. Therefore, these conclusions need to be made sparingly, with adequate documentation of the reasons for the conclusion (such as consistency, directness, low risk of bias, and large sample size). Reviewers need to be transparent and clear about these judgments; conclusions of EQ/NI may require additional studies following the failure of superiority trials to show a difference.

### Whether the Meta-Analytic Model Was Random Effects

The EPC guidance chapter on quantitative methods43 recommends that meta-analyses employ a random-effects model rather than a fixed-effects model. One reason for this is that the random-effects confidence interval incorporates heterogeneity, whereas the fixed-effects model ignores it. This recommendation may be even more appropriate in the context of concluding equivalence or noninferiority. Under heterogeneity, a fixed effects model may lead to an inappropriate EQ-NI conclusion due to its inappropriately narrow interval. As discussed in the EPC guidance chapter on pooling,44 however, a random-effects model does not actually explain the heterogeneity, and meta-regressions or subgroup analyses can be used for this purpose.

One technical point involving meta-analysis: Noninferiority trials may report a one-tailed confidence interval because of the one-sided nature of the authors’ hypothesis. If the systematic reviewer also chose a priori to approach the question from a one-sided perspective, this interval can be used for the purpose of inclusion in a one-tailed meta-analysis (which may require customization of meta-analysis software). However, if instead the reviewer intended to compare the treatments from a two-sided perspective (i.e., either direction of effect is possible), then the one-sided interval should be used to determine the standard error of the study’s effect size, which should then be used as a measure of within-study error in a standard two-sided meta-analysis. Any conclusion of equivalence should be supported by a two-tailed confidence interval.

### Whether the Confidence Interval Was Narrow Enough To Rule Out an MID

For demonstrating equivalence or noninferiority, the confidence interval should be narrow enough to exclude the MID. Figure 1 demonstrates different scenarios of effect estimates in a noninferiority framework. In scenario A, the test intervention is significantly better than the active comparator. If the magnitude of effect is larger than a clinically important difference for superiority, one may further claim the superiority of the test intervention over the active comparator. Scenarios B and C in the figure represent situations in which a new intervention is non-inferior to an active comparator. Scenario C represents a situation of extreme precision that could permit multiple conclusions, and we discuss these in detail in Section 4: Language Considerations When Concluding EQ or NI. In scenarios D and E, the confidence interval is too wide to exclude the MID, and no conclusive decision can be made. Scenario F represents a situation in which the test intervention is inferior to the active comparator.

Figure 1 Example scenarios comparing the confidence interval with the MID

Notes: The figure shows a noninferiority comparison of test intervention to active comparator. Only the right-side MID line is shown because it is noninferiority; if it had been equivalence, both the right-side MID and the left-side MID would appear. Also the example involves a dichotomous outcome and a relative effect size metric (e.g., relative risk). If the outcome were continuous, the vertical line of no difference w be 0 and the MID would be set at on that scale.

Scenario A: comparison showing superiority; B and C: comparisons showing noninferiority; D and E: comparison showing inconclusive evidence, and noninferiority cannot be claimed; F: comparison showing inferiority; H: comparison apparently showing noninferiority; due to the small events or sample size, however, the conclusion is unstable, and could easily be overturned by new evidence (e.g., I).

Figure 1. Example Scenarios Comparing the Confidence Interval to the MID. A line graph where vertical lines are 1 and MID and horizontal lines are scenarios A through I. Notes: The figure shows a non-inferiority comparison of test intervention to active comparator. Only the right-side MID line is shown because it is non-inferiority; if it had been equivalence, both the right-side MID and the left-side MID would appear. Also the example involves a dichotomous outcome and a relative effect size metric (e.g., relative risk). If the outcome were continuous, the vertical line of no difference were be 0 and the MID would be set at on that scale. Scenario A: comparison showing superiority; B and C: comparisons showing non-inferiority; D and E: comparison showing inconclusive evidence, and non-inferiority cannot be claimed; F: comparison showing inferiority; H: comparison apparently showing non-inferiority; due to the small events or sample size, however, the conclusion is unstable, and could easily be overturned by new evidence (e.g., I).

Scenario H is a special case in which the test intervention appears non-inferior to the active comparator. However, substantial uncertainty exists due to a small number of studies and/or events. In this situation, when a new study is published (e.g., study I in the figure), the resulting summary confidence interval could then cross the noninferiority line, thereby eliminating the conclusion. When further evidence appears, reviewers should consider the possibility of a shift in the confidence interval resulting in a change of conclusion. Reviewers should discuss in their reports the extent to which their conclusion of noninferiority is susceptible to new evidence.

As an example, Meier et al.45 performed a meta-analysis of defibrillation-first versus compression-first strategy for patients with cardiac arrest. One of the measured outcomes was survival until hospital discharge, and the minimum important difference was an odds ratio of 1.25. The summary odds ratio of defibrillation versus was 1.10, with a 95 percent confidence interval from 0.70 to 1.70. This falls into scenario D, thus no conclusion can be reached, because the evidence was consistent with both (1) a clinical advantage of the active comparator and (2) an advantage of the test intervention. If the confidence interval had ranged from 0.8 to 1.15, the comparison would falls into scenario B, permitting a noninferiority conclusion.

### Strength-of-Evidence Considerations

We examined the eight domains of SOE described by Owens et al.41 and considered which domains should be treated differently if the evidence indicates EQ-NI. Section 1 of this guidance document already discussed how risk of bias assessment would be altered. For three other domains (consistency, directness, and publication bias), an EQ-NI situation does not appear to introduce unique considerations. They should be considered regardless of the type of conclusion. For the domain of precision, a conclusion of EQ-NI depends on sufficient precision because the idea is to rule out the possibility of a minimum important difference on that outcome. In many cases, the evidence is too imprecise to rule out such a difference, resulting in a rating of Insufficient, and no conclusion to be drawn about that outcome.

Three other domains (magnitude of effect, all-plausible-confounders-would-reduce-the-effect, and dose-response association) appear to work in the opposite direction for EQ-NI conclusions as compared to superiority conclusions. The SOE rating system described by Owens et al.41 was designed with the assumption of a superiority conclusion. These three domains underscore that assumption. For a superiority conclusion, the SOE was stated to increase if the following were observed:

1. a large magnitude of effect, or
2. a difference between treatments despite studies being biased against an effect, or
3. a positive dose-response association.

If the evidence actually suggests equivalence, then the following observations would increase the SOE:

- The evidence for equivalence might be considered stronger if the effect is very small. Thus the magnitude-of-effect domain works in the opposite direction than it does for a superiority conclusion.
- The evidence for equivalence might be considered stronger if the studies were biased in favor of one of the two treatments (and yet the evidence found equivalence). Again, the domain works in the opposite direction than it does for a superiority conclusion.
- The evidence for equivalence might be considered stronger if the studies showed a clear lack of a dose-response association (when the comparison is drug vs. drug).

For example, if two drugs appear to have similar effects regardless of the dose of either, that may increase the strength of evidence for the conclusion of equivalence. Again, the domain works in the opposite direction than it does for a superiority conclusion.

### Bayesian Analysis

Bayesian analysis methods in medicine involve the statistical combination of a prior (probability) distribution with a likelihood distribution based on observed data from one or more clinical trials or a meta-analysis.46 When used to compare two or more medical interventions, the result is an updated posterior (probability) distribution that reflects a true absolute or relative difference between them along with 95 percent credible intervals (CrIs, e.g., the 2.5 and 97.5 percentiles of the posterior distribution). In addition to reporting an effect size and 95 percent CrIs, the posterior distribution can also be interpreted in terms of an estimate of the probability that a given treatment is better than its comparator(s) (e.g., “There is an x percent probability that an intervention results in a greater response than another intervention”). For this reason, many believe that Bayesian methods are more directly relevant and easily interpretable to medical decisionmakers and health care professionals.

Bayesian methods can also be used in the determination of noninferiority or equivalency of two or more medical interventions. After the posterior probabilities reflecting the difference between the two (or more) interventions are constructed, the observation that the 95 percent credible interval (CrI) falls entirely to one side of the MID would define NI (see Figure 2). A simple extension of this methodology could be used to determine EQ.

Figure 2 Bayesian posterior distribution compared with the MID

Note: This figure has been adapted from Quilici, et al.47 The hypothetical bell-shaped curve is the posterior probability distribution (i.e., after the data have been incorporated). The leftmost vertical dashed line indicates a hypothetical MID of about 0.90 relative risk. The Bayesian 95% credible interval (the other two vertical-dashed lines) is fully above this line, which means that the evidence is sufficiently precise to permit a conclusion of noninferiority.

Figure 2. Bayesian posterior distribution compared to the MID. A line graph with a bell curve. The hypothetical bell-shaped curve is the posterior probability distribution (i.e., after the data have been incorporated). The leftmost vertical dashed line indicates a hypothetical MID of about 0.90 relative risk. The Bayesian 95% credible interval (the other two vertical dashed lines) is fully above this line, which means that the evidence is sufficiently precise to permit a conclusion of non-inferiority.

As with frequentist approaches to clinical trial interpretation, an a priori-specified MID should be determined using both statistical and clinical reasoning.9

### Non–Meta-Analytic Situations

A conclusion of EQ or NI requires the ability to rule out the possibility of a MID (see above), and this is typically done by examining the confidence interval around the summary effect of a meta-analysis (or if there is only a single study, then one examines the single-study confidence interval). Some multiple-study situations, however, may not be appropriate candidates for meta-analysis.

The decision to combine studies in a meta-analysis depends on the clinical and methodological similarity of the studies. As described in Chapter 9 of the Methods Guide for Effectiveness and Comparative Effectiveness Reviews, there is no commonly accepted standard of defining which studies are “similar enough.”19 The decision to combine studies depends on the focus of the research question and on the extent of clinical, methodological, and statistical heterogeneity present among the included studies. The reviewer must decide how much heterogeneity is excessive. In general, meta-analysis is considered inappropriate when there is considerable clinical heterogeneity among factors such as patient populations, treatment implementation, and/or outcome measures. Meta-analysis may also be inappropriate in cases where studies measured the same outcome in disparate ways (e.g., different quality-of-life measures), or studies do not report the necessary information to allow meta-analysis, or such information cannot be calculated from reported information (for example, when the Ns at followup are not reported).

The research question and the overall strength of the evidence, not just the appropriateness of meta-analysis, are what should form the basis of any conclusion within a systematic review. The presence of clinical heterogeneity among studies indicates that the studies are really addressing different questions. Thus, each study should be considered individually (i.e., the single-study CI) when determining whether its clinical question warrants a conclusion. For example, suppose three studies are included for a review’s “Key Question 2” on treatments for diabetes. Further suppose the three studies were clinically heterogeneous in that they enrolled different populations (one study enrolling children with type 1 diabetes, another study enrolling adults with type 1 diabetes, and a third study enrolling adults with type 2 diabetes). The three studies address clinically distinct issues, and should be treated as three subquestions (i.e., Key Questions 2a, 2b, and 2c). Any one of these three evidence bases could permit a conclusion of EQ-NI, as long as the strength of the evidence was not judged to be Insufficient. As always, whether the evidence is sufficient to permit a conclusion depends on many factors such as the risk of bias, directness of the evidence, consistency, and precision (e.g., does the study’s CI fall within the margin of EQ-NI). See Owens et al.41 for how to assess these factors.

Thus, the lack of meta-analysis does not necessarily preclude a conclusion of EQ-NI, just as it does not preclude an evaluation of the strength of evidence in relation to a particular outcome. The same approach should also be used for determining if studies appropriately form a body of evidence for evaluating one outcome in relation to one key question. Reviewers should still evaluate the analytic foundations discussed above, as they would prior to conducting a meta-analysis. In particular, the MID should be determined a priori. However, the reviewer will need to qualitatively determine what the MID should be for each study and what would be considered comparable across studies. In the case of different measures of the effectiveness of an intervention or outcome (such as the use of different measurement scales or instruments), the reviewer will need to be knowledgeable of what might be considered a MID for each of the included measures. The reviewer will also need to compare studies in relation to their choice of potential confounding variables controlled in analyses because these could result in differences in effect size.

Studies sometimes do not report effect sizes and confidence intervals, but these can usually be calculated based on reported information. For example, for dichotomous outcomes, studies sometimes do not report a relative risk and its standard error, but these are easily calculated from the reported rates and Ns. For continuous outcomes, studies often fail to report measures of dispersion (e.g., standard deviations or SDs). It may be appropriate to impute SDs for those studies based on other studies that did report SDs.48,49 If such imputation is too uncertain, and no confidence interval can be determined, then the reviewer cannot rule out the possibility of an MID; thus no conclusion of EQ-NI can be drawn.

## Section 4 Language Considerations When Concluding EQ or NI

Clear communication can be particularly difficult when drawing conclusions of EQ-NI, and a key emphasis should be on preventing misinterpretations. For example, concluding only that “there was no statistically significant difference” can be factually correct, but highly misleading. The problem is that the statement fails to distinguish between two very different scenarios:

1. the evidence shows equivalence, and
2. the evidence is inconclusive due to low statistical power.

The first scenario should be expressed more directly (e.g., “the treatments had similar mortality rates”), whereas the second scenario indicates insufficient evidence (i.e., no conclusion).

Similar criticism can be leveled at the wording “no evidence of a difference.” This can be misinterpreted by users that the reviewer has concluded “evidence of no difference.” Other indirect wordings to be avoided include “studies failed to show a difference,” “studies did not find/suggest/show/indicate a difference,” “trials have not found a difference.” None of these wordings distinguish between a conclusion of equivalence and a non-conclusion due to low precision. The processes detailed in the other three sections of this guidance, involving comparing the confidence interval to the MID as well as assessing all other aspects of the strength of evidence, together determine whether the evidence is sufficient to permit a conclusion of equivalence.

The main question in an equivalence study is whether a new treatment is therapeutically similar to the current standard of care. As indicated above, the most common problem observed among studies that claim equivalence is the misinterpretation that lack of a statistically significant difference between treatments is evidence of equivalence. This guidance document highlights that conclusions of equivalence should be based on whether the confidence intervals fall within the prespecified margin of EQ. If the confidence intervals indicate EQ, reviewers (as well as trial authors) could use the following terminology to phrase their conclusion: “Treatment A is equivalent to Treatment B,” “Treatment A is similar to Treatment B,” or “Treatment A improves recovery [or whatever outcome] as much as Treatment B.”

In contrast, the main question in a noninferiority study is whether a new treatment is not worse than the current standard of care by a prespecified amount. Thus, when drawing a conclusion of NI whether in an individual trial or a systematic review, the conclusion should be worded to indicate that the test intervention is noninferior to the active comparator. And not, as previously mentioned in this guidance document, phrased in the reverse—the active comparator is non-inferior to the test intervention. Phrases that are commonly used to express noninferiority include: “Treatment A is not inferior to Treatment B,” or “Treatment A is at least as effective as Treatment B.”

To be complete, a conclusion of EQ-NI should include a description of the study objectives. For example, Bingham et al. conducted two identical noninferiority trials in which the primary purpose was to determine whether etoricoxib 30 mg daily was as effective as the recommended dose of celecoxib 200 mg daily in patients with osteoarthritis.50 The authors of the study stated their conclusion as follows: “Etoricoxib 30 mg q.d. was at least as effective as celecoxib 200 mg and had similar safety in the treatment of knee and hip OA [osteoarthritis].” Similarly, ECRI Institute conducted two systematic reviews comparing the efficacy and safety of inhaled insulin to short-acting injected insulin—one addressing type 1 diabetes51 and the other type 2 diabetes.52 The primary purpose of the reviews was to determine if inhaled insulin provided similar glucose control to short-acting injected insulin. In both reviews, the authors concluded that “inhaled insulin and injected insulin provided similar levels of glycated hemoglobin” in the short-term (12 and 24 weeks).

Some reviews use qualifiers (e.g., “may,” “suggest”) when drawing conclusions. These words are intended to convey degrees of reviewer confidence in the evidence. Strength-of-evidence ratings, similarly, are intended to communicate one’s confidence. Thus, they can replace the need for language qualifiers. Instead of using a language qualifier (“Survival rates after treatments A and B may be similar”), one could make a simple declarative statement and pair it with a strength rating (e.g., “Survival rates after treatments A and B are similar [Strength of Evidence: Low]”). Some EPCs may choose to use both the rating and a language qualifier. If so, reviewers should be aware of potential inconsistency (e.g., “The evidence suggests that quality-of-life after Treatment A is similar after Treatment B [Strength of Evidence: High]”).

As described in the previous section, Bayesian analysis can permit other options for communicating conclusions of EQ-NI. For example, based on an appropriate posterior distribution, a reviewer might state “there is a 96 percent chance that the true difference between the treatments is less than the MID,” or “the chance is 98 percent that treatment A is not inferior to treatment B on this outcome.”

Sometimes, the evidence is so precise that it is simultaneously compatible with multiple conclusions. For example, Weng et al.53 meta-analyzed 11 trials comparing the percentage change in LDL after atorvastatin 10 mg vs. simvastatin 20 mg. The summary confidence interval was +1.2 percent to +3.1 percent, in favor of atorvastatin. This was statistically significant, but less than the reviewers’ MID of 7 percent. What should the reviewer do?

Technically, the data are consistent with four conclusions:

1. Atorvastatin is superior to simvastatin (because the CI was above 0);
2. Atorvastatin and simvastatin are approximately equivalent (because the CI was within the range -7 percent to +7 percent);
3. Atorvastatin is noninferior to simvastatin (because the CI was above -7 percent); and
4. Simvastatin is noninferior to atorvastatin (because the CI was below +7 percent).

The latter two conclusions, which are NI conclusions, are not relevant to these drugs because neither drug was known in advance to have advantages on other outcomes. The real question is whether to conclude superiority (conclusion 1) or equivalence (conclusion 2).

One option would have been to present only the superiority conclusion, based on the fact that the MID itself is a subjective judgment, and some patients or clinicians may have lower MIDs for LDL. One might argue that a reviewer’s responsibility is to report all observed differences, no matter how small. Another option is to present only the equivalence conclusion, based on the fact that users of the review need not be bothered by such small differences among treatments, differences that were clearly considered unimportant by the reviewers. A third option is to combine the conclusions into one, as done by Weng et al.: “Meta-analysis indicated a statistically significant but clinically minor difference (<7 percent) between statins in cholesterol lowering effect.”53 This option fully describes the data, and absolves the reviewer from having to prioritize one conclusion over the other.

Choosing among these options is a reviewer judgment based on the context of the review, and one’s certainty in the MID for that outcome. In the statin example, the abstract’s Results section contained the joint statement quoted above, but the abstract’s Conclusion section stated more simply “At comparable doses, statins are therapeutically equivalent in reducing LDL-C.”53 Thus, the authors prioritized the equivalence conclusion over the superiority conclusion. This suggests they were fairly confident about their 7 percent MID for percentage change in LDL. Other clinical situations may warrant other approaches.

This section has addressed language for when the evidence permits a conclusion of EQ-NI. Language for phrasing a superiority conclusion is straightforward. If no conclusion is possible from the evidence on that outcome (i.e., one cannot conclude equivalence or noninferiority or superiority), then care should be taken to use balanced and non-suggestive wording, such as “the evidence was insufficient to permit a conclusion for this outcome.”

## Examples

Beauchamp, et al.,54 performed a CER comparing two types of exercise training for chronic obstructive pulmonary disease:

- For the Chronic Respiratory Questionnaire domains of dyspnea and total score (on which scores range from 1 to 7), authors chose 0.5 as the minimal important difference. In support of this value, they cited an earlier systematic review from other authors that had delved into existing research on the questionnaire itself, and found converging evidence to support the choice of 0.5. For the outcome of functional exercise capacity, authors chose 54 meters difference in 6-minute walking distance. To support this choice of MID, they cited a study that had empirically determined that 54 meters was the distance at which “the average patient to stop rating themselves as ‘about the same’ and start rating themselves as either ‘a little bit better’ or ‘a little bit worse’”. Systematic reviews only rarely have such sound foundations for the chosen MIDs, but it can happen.
- Of the four trials reporting these outcomes, one self-identified as a noninferiority trial, and the other three did not self-identify as either superiority/noninferiority/equivalence trials. Instead, the three studies’ stated goal was generally to compare the two treatments. Risk-of-bias assessment methods were not altered for the one trial self-identifying as a noninferiority trial. Thus, authors did not feel that the risk of bias of the NI trial should be measured differently because it was an NI trial.
- The reviewers performed a meta-analysis including all four trials (one NI trial and three non-self-identifying trials), because of their similarities in patients, treatments, outcomes, and time points. The 95 percent confidence interval was fully within one MID of 0 for both outcomes, providing statistical support for a conclusion of equivalence.
- Authors concluded: “The results of this meta-analysis suggest that there are no differences between the effect of interval and continuous training on measures of exercise capacity or on health-related quality of life in individuals with moderate to severe COPD.”54 This wording clearly indicates equivalence, and successfully avoids the impression that reviewers believed the evidence was insufficient to permit a conclusion.
- Eyawo et al.55 compared three different types of proglandin therapy in the treatment of open-angle glaucoma and ocular hypertension:
- For the efficacy outcome of intraocular pressure, authors set the MID at 1.5 mmHG. They stated that this was a “commonly used margin of equivalence,” and they cited a trial that addressed the same medical condition but was not included in the review.
- Seven out of 16 studies had set their own MIDs. The review did not report whether the seven MIDs matched the authors’ selected MID.
- One of the 16 trials mentioned in its abstract that authors tested noninferiority; none of the other 15 studies’ titles or abstracts had self-identified as superiority trials, equivalence trials, or noninferiority trials. The risk of bias was assessed in the same way for all trials.
- Authors performed pairwise comparisons of three drugs, and reported the three meta-analytic confidence intervals. Two were fully within 1.5 of 0 (i.e., permitting a conclusion of equivalence), and the third was slightly over (0.13 to 1.63 mmHg). They did find drug differences in rates of conjunctival hyperemia.
- Authors concluded: “Randomized head-to-head evaluations of prostaglandin therapy demonstrate similar efficacy effects but different hyperemia effects.” This is a straightforward conclusion of equivalence on efficacy.

## Summary of Recommendations

The two tables below summarize the recommendations. Table 3 involves risk of bias considerations for individual trials that self-identify as equivalence trials or noninferiority trials. Table 4 involves systematic review conclusions of either equivalence or noninferiority, specifically the a priori specification setting of the minimum important difference (MID), analytic considerations to support a reviewer conclusion of EQ or NI, and language considerations when a reviewer does conclude EQ or NI.

Table 3 EPC guidance on risk-of-bias considerations for trials self-identifying as equivalence or noninferiority trials

Recommendations (“Do’s”) | Issues to Avoid (“Don’ts”)
- Assess studies for the following areas of particular concern: poorly implemented entry criteria, poor adherence, use of concomitant treatments, protocol violations, and inadequate measurement techniques.; - Assess studies for similarity to trials that established efficacy of the active comparator.; - Specify how studies included in a review will be compared to placebo-controlled trials that established the efficacy of the active comparator (e.g., technical expert panel input, comparison with previous reviews of comparisons of the active comparator with placebo-control).; - Focus on the design and conduct of the studies.; - Set up clearly stated and consistent standards for how to deal with the issue of poor reporting. | - Do not focus exclusively on the quality of reporting

Table 4 EPC Guidance on drawing conclusions of equivalence and noninferiority

Area of Consideration | Recommendations (“Do’s”) | Issues to Avoid (“Don’ts”)
Setting the reviewer’s Minimum Important Difference (MID) | - Define the margin of EQ-NI based on the MID, which incorporates the patient and clinical perspective.; - Prespecify MID and justify choice of the value in a systematic review, ideally using prior research on what matters to patients.; - Examine the reported MID in trials of EQ-NI for primary outcomes and examine the trial authors’ justification for their choice.; - If an author’s MID is used as justification for the reviewer’s MID, ensure that the author stated it to be the “minimum” difference considered important.; - Consider sensitivity analysis using multiple definitions of MID, if uncertainty about the chosen MID is substantial.; - For subjective outcomes, consider using anchor-based margins. Anchor method compares patient opinion with scale score and may include perception of improvement in disease status, function, disability or quality of life.; - Define MID as the difference between treatment groups, not as change from baseline.; - Include MIDs in review for the same primary outcomes reported in individual trials of EQ-NI. | - Do not ignore the authors’ stated MID in individual trials of EQ-NI
Analytic foundations for concluding EQ or NI | - Drawing conclusions of EQ-NI should be considered within the wider context of rating the strength-of-evidence (SOE).; - Noninferiority conclusions require prior knowledge that one of the treatments was better on some outcomes (e.g., safety, cost, convenience) in order to justify a small sacrifice in effectiveness in a predefined direction.; - Consider including a supplemental evidence review on the comparison of the active comparator vs. placebo (or inactive control) to establish that the active comparator is itself effective.; - Determine whether the confidence interval around the effect size is narrow enough to exclude the MID.; - Consider that other aspects of SOE need to be treated in the opposite manner, such as magnitude of effect, all-plausible-confounders-would-reduce-the-effect, and dose-response association.; - Consider other analytic approaches (e.g., Bayesian methods). | - Conclusions of EQ-NI should not be based solely on the lack of statistical significance between two treatments.; - Do not require meta-analysis.
Language considerations when concluding EQ or NI | - Avoid confusion or misinterpretation when wording conclusions of EQ-NI.; - Use direct phrasing to express an EQ-NI conclusion, or if the evidence is inconclusive, state that.; - For examples of direct phrasing, consider phrasing such as “not inferior to,” ”similar to,” “comparable to,” or “at least as effective as” when expressing EQ or NI.; - Include a description of the study objectives when concluding EQ or NI.; - Consider using SOE rating in place of language qualifiers to express uncertainty. If both are used, be aware of potential inconsistencies.; - If no conclusion is warranted (i.e., the evidence is insufficient to conclude neither superiority, nor equivalence, nor noninferiority), use balanced and non-suggestive wording, such as “the evidence was insufficient to permit a conclusion for this outcome.” | - Avoid indirect wording that fails to distinguish between an EQ-NI conclusion and insufficient evidence. Examples to avoid are “no evidence of a difference,” “there was no statistically significant difference,” “studies failed to show a difference,” “studies did not find/suggest/show/indicate a difference,” “trials have not found a difference.”