# Peer Reviewers

Jeffrey Andrews, M.D., FRCSC

Vanderbilt Evidence-based Practice Center

Nashville, TN

Ethan Balk, M.D., M.P.H.

Tufts Evidence-based Practice Center

Boston, MA

Jesse Berlin, Sc.D.

Johnson & Johnson Pharmaceutical

New Brunswick, NJ

Tianjing Li, M.D., Ph.D., M.H.S.

Johns Hopkins Bloomberg School of Public Health

Baltimore, MD

James Reston, Ph.D., M.P.H.

ECRI Institute

Plymouth Meeting, PA

Norma Terrin, Ph.D.

Tufts Medical Center

Boston, MA

Lucy Turner, M.Sc.

Ottawa Health Research Institute

Ottawa, Ontario, Canada