# Acknowledgements

We appreciate the comments and suggestions on an earlier draft of this guidance from several peer reviewers and public commenters, as well as Karen Schoelles, M.D., S.M., FACP, Wendy Bruening, Ph.D., and Irena Kirman, M.D., Ph.D.