# Methods Project 2: Review of Recent Systematic Reviews That Concluded Equivalence or Noninferiority

## Purpose

The purpose of this document is to assess current practices used within published systematic reviews that contain conclusions that could be interpreted as conclusions of equivalence or non-inferiority (EQ/NI) between two or more treatments. The information presented in this document is intended to aid in the development of guidance for Evidence-based Practice Centers (EPCs) to follow when drawing conclusions of EQ/NI in the context of comparative effectiveness reviews (CERs). This document focuses on current practices related to the following areas within systematic reviews: assessing risk of bias, defining the minimum important difference (MID, or margin of EQ/NI), analytical basis for drawing conclusions of EQ/NI, and wording of conclusions of EQ/NI.

## Methods

To evaluate current practices, we first identified recently published systematic reviews that contained an author’s conclusion that could be interpreted as a conclusion of EQ/NI. A searcher from the Scientific Resource Center (SRC) conducted a search of systematic reviews or meta-analyses. The following inclusion criteria were applied to identify potentially relevant documents:

- A systematic review or meta-analysis indexed in MEDLINE in 2010 to present.
- Published in a peer-reviewed journal within one year of the search date. The focus on recent reviews is to give maximal relevance to today’s review processes, and also to permit us to finish the project on schedule.
- Compared outcomes after two or more medical treatments.
  ○ The title or abstract or executive summary contained an author’s conclusion that could be interpreted as equivalence or non-inferiority. This was approached leniently. The authors did not have to actually use the word “equivalent” or “non-inferior” or “similar.” Wording such as “the treatments appear to not differ substantially” or “there was no statistically significant difference” would qualify because these statements could be interpreted as conclusions of equivalence. But this sort of statement must have appeared in either the title or abstract or executive summary, for two reasons: (1) to ensure that it was truly a conclusion of the authors (and not simply a vague “by the way” buried in the discussion section), and (2) it would be too resource intensive to go through the full text of all of the reviews that may have drawn a conclusion of EQ/NI somewhere within the full text.

The search identified 961 potentially relevant documents. The abstracts were reviewed by three ECRI Institute analysts (KT, SU, and JT). A total of 235 documents met the inclusion criteria described above. The remaining 726 documents did not meet the inclusion criteria for one of the following reasons: (1) the document was not a systematic review/meta-analysis, (2) the document did not assess the efficacy of two or more active treatments, or (3) the document did not contain an author’s conclusion that could be interpreted as a conclusion of EQ/NI. From the pool of 235 remaining systematic reviews, a random sample of 50 was selected (using the random numbers function in Excel) for further review and data abstraction. From these reviews, two ECRI Institute analysts (KT and SU) abstracted the information listed in Table 1.

### Characteristics of Included Systematic Reviews

Overall, the stated purpose of 46 of the 50 randomly selected systematic reviews was to compare the efficacy and safety of two or more medical treatments. Thus, the authors of the reviews did not generally define their review as a specific type of systematic review such as an “equivalence review.” In one review, the authors specifically indicated that the purpose of the review was to determine if one treatment was not inferior to another treatment.1 In three reviews, the authors specified that the purpose of the review was to determine whether one treatment was superior to or better than another treatment.2–4 See Table for further details on the characteristics of each review assessed in this document.

The medical conditions and interventions covered in the systematic reviews were wide ranging. The medical conditions included various types of cancers, cancer related pain, heart disease, autoimmune disorders, diabetes, chronic wounds, osteoarthritis, infertility, dental disease, Alzheimer’s disease, seizure disorders, and depression. In most of the systematic reviews, a newer or less frequently used treatment was compared to what would be considered the standard or conventional treatment for the medical condition under consideration. The interventions compared included partial breast irradiation versus whole breast irradiation, transdermal fentanyl versus sustained-released oral morphine, drug-eluting stents versus bare metal stents, intensive glucose control strategies versus conventional glucose control strategies, radiofrequency ablation versus surgical resection, and cognitive behavioral therapy plus antidepressant therapy versus antidepressant therapy alone.

In all of the reviews the included studies were comparative studies of two or more treatments, with most reviews including only randomized controlled trials of head-to-head comparisons of treatments (34/50). However, some reviews included non-randomized controlled trials, cohort trials, and/or observational trials. The evidence base of the systematic reviews ranged from 3 to 69 included trials, with the number of included patients ranging from 96 to 28,065. In none of the systematic reviews did the authors report if any of the included studies were designed to be EQ/NI trials.

### Assessing Risk of Bias

In the document developed for Methods Project 1, which summarizes existing guidance for individual trials of EQ/NI, the author describes a number of factors related to conducting and analyzing EQ/NI trials that may be important when assessing the risk of bias of studies included in a systematic review of these types of trials. These factors include the following:

- Vague or inconsistently applied patient enrollment criteria
- Biased selection of patients (e.g., selecting patients for anticipated nonresponse or relatively high response)
- Poor compliance with treatment
- Use of concomitant treatments that mask the true treatment effect
- Inappropriate dosage of treatment or differences in amount of treatment
- Patients not receiving treatment as assigned or crossing over to other treatment group
- Dropout/attrition
- Inadequate measurement of outcomes
- Not blinding outcome assessors
- Not performing both intention-to-treat and per-protocol analysis

While none of the authors of the systematic reviews assessed in this document reported if any of the trials included in their review were designed specifically to be EQ/NI trials, most authors (42/50) did report using some method to assess the risk of bias or quality of the included studies (See Table 3).^1^ In most of the reviews, the authors reported using a recognized method, instrument, or checklist to assess risk of bias. These include: Jadad scale (12 reviews), the method described in the Cochrane Handbook (4 reviews), Newcastle-Ottawa Quality Scale (3 reviews), PEDro scale (3 reviews), and other (9 reviews).^2^ The authors of 11 reviews did not report using any specific method or instrument to measure risk of bias, but did describe aspects of bias within the studies included in their review that could limit the conclusions of the review. These factors include: allocation of concealment; adequacy of randomization; baseline comparability; blinding of patients, clinicians, and outcome assessors; completeness of data reporting; documentation of dropouts/loss to follow-up; use of intention-to-treat analysis; and source of funding.

1 The authors of eight reviews did not report using any method to assess the risk of bias and did not discuss limitations related to bias within the studies included in their review.

2 In some of the reviews, the authors used more than one instrument, especially in reviews that included studies with different research designs (e.g., controlled trials and observational studies). The “other” category includes methods of assessing risk of bias in which the authors combined questions from various assessment instruments.

Interestingly, the use of intention-to-treat (ITT) analysis was considered good practice in the included trials, and yet the reviewers ended up concluding EQ/NI. As detailed in the summary document for Methods Project 1, the use of ITT tends to increase the chance of an incorrect conclusion of EQ-NI where in fact there is a true difference.

Overall, the quality of the controlled trials included in the reviews that reported on overall quality was moderate. The authors of these reviews indicated that the quality of the studies was limited due to lack of concealment of randomization, not blinding or not reporting if the outcome assessors were blinded, and not reporting if an intention-to-treat analysis was performed.

### Method of Defining Minimum Important Difference

In only three systematic reviews did the authors define an MID for some of the outcomes considered in their review (See Table 4).5–7 In one review that compared the effects of interval versus continuous exercise training on peak oxygen uptake, peak power, 6 minute walk test (6MWT) distance, and health-related quality of life in individuals with chronic obstructive pulmonary disease, the authors defined the MID for quality of life as measured by the Chronic Respiratory Questionnaire (CRQ) as a difference 0.5 for domains of dyspnea and total score and as a difference of 54 meters for the 6MWT.5 The definitions of MID used in this review were pre-specified and based on previously published studies assessing the test properties of the CRQ and 6MWT.

In another review that evaluated the beneficial effect of chest compression-first versus defibrillation-first on survival of patients with out-of-hospital cardiac arrest, the authors defined a clinically relevant change for the primary outcome of survival to hospital discharge as a change of 20 percent to 25 percent.6 The values used in this review were pre-specified and based on previously published studies evaluating interventions for out-of-hospital cardiac arrest, such as pre-defibrillation chest compressions and therapeutic hypothermia. In the final review, which evaluated the comparative data of commonly prescribed monotherapy drug regimens for both manic and depressive phases of bipolar 1 disorder, the authors calculated effect sizes for the number needed to treat and the number needed to harm.7 For these outcomes, the authors considered an effect size of fewer than 10 patients as clinically meaningful. This value was pre-specified and based on a previous publication by Kraemer and Kupfer (2006) that discusses the size of treatment effects and their importance to clinical research and practice in psychiatry.

The authors of the reviews did not indicate that the MID defined in their review was to be used as a margin for determining if the treatments being evaluated were equivalent or not inferior to each other. However, based on the results of their meta-analysis, the authors of one review concluded that the treatments being evaluated appeared to be equivalent.6 In this review, the meta-analysis indicated no statistically or clinically significant difference between the treatments being compared. Based on similar meta-analytic results, the authors of the two other reviews concluded that there was no difference between the treatments being compared in their review, but did not specifically indicate that the treatments were equivalent or similar to each other.5,7

### Analytic Basis of Drawing Conclusion of Equivalence or Non-inferiority

In the majority of the reviews (43/50) the authors based their conclusions of EQ/NI on meta-analytic findings of no statistically significant difference between treatments. Few reviews considered whether the evidence was sufficient to rule out a clinically important difference. In most reviews (39/50), the authors performed meta-analysis using either a fixed (Mantel-Haenszel or Peto method) or random (DerSimonian and Laird method) effects model. The specific model used in most cases depended on the presence of significant heterogeneity, which was typically measured using the I^2^ statistic. Individual and pooled summary effect size estimates were calculated with 95 percent confidence intervals (95 percent CIs) using the following metrics depending on the type of data reported: odds ratio, relative risk ratio, hazard ratio, or weighted mean difference. In one review, when appropriate, the authors conducted indirect analyses of the evidence using the method described by Butcher, et al.8 In four reviews, the authors either didn’t report the meta-analytic model used to perform meta-analysis or reported using a method other than that described by Mantel-Haenszel or DerSimonian and Laird. The meta-analytic results (summary effect size estimate with 95% confidence intervals) of each review are presented in Table 5.

In seven of the systematic reviews no meta-analysis was performed. Instead, the authors of these reviews based their conclusions on a qualitative assessment of the evidence.9–14 In two reviews, the authors indicated that no meta-analysis was performed due to the presence of clinical heterogeneity (e.g., differences in comparators used and outcomes measured across studies).10,15 The authors of these reviews reported using vote counting (i.e., counting the number of studies supporting and not supporting the intervention) of the overall trials to draw conclusions. Based on this method, the authors of one review concluded that “the antiseptic effect of iodine is not inferior to that of other (antiseptic) agents and does not impair wound healing.”10 The authors of the other review concluded that “current evidence indicates that there appears to be no [disease free survival] advantage [of the addition of neoadjuvant transarterial chemoembolization for resectable hepatocellular carcinoma] despite its safety and feasibility.”15

In the remaining five reviews, the authors did not report their reasons for not performing a quantitative analysis of the evidence nor did they report using an alternative method such as vote counting. In these reviews, the findings of the included studies were narratively summarized and the authors based their conclusions on the narrative synthesis of the evidence.

### Wording of Conclusions within Systematic Review

In Appendix E

Table 6 (Appendix E), we present the exact wording of the authors’ conclusions as reported in the abstract or discussion section of each review. As indicated in previous sections of this document, none of the authors of the reviews used a margin of EQ/NI (as defined as the minimal important difference) to determine if the treatments being considered in their review were equivalent or non-inferior to each other. Thus, the conclusion statements described in this section are based primarily on meta-analytic results that indicated no statistically significant difference (or in a few cases no clinically significant difference) between the treatments being assessed. According to many of the regulatory documents reviewed in Methods Project 1, it is inappropriate to draw a conclusion of EQ/NI solely on the basis of a non-significant difference. The reason being that a non-significant difference alone does not discriminate between two very different situations: (1) “when the confidence interval is narrow enough to exclude the possibility of a meaningful difference, and (2) when the confidence interval is too wide to permit any conclusion about whether the treatments differed.”

We assessed the specific wording used in the authors’ conclusions of each review to determine how many used direct terms of EQ/NI such as “equivalent to,” “similar to,” “comparable to,” and “not inferior to.” Overall, the conclusion statements of 19 reviews used direct terms of EQ/NI. Examples include the following:

- “Currently available evidence suggests a similar effectiveness of GNRH antagonists and agonists in the context of oocyte donation.”
- “Current evidence does not support the notion that chest compression first prior to defibrillation improves the outcome of patients in out-of-hospital cardiac arrest. It appears that both treatments [chest compressions first vs. defibrillation first] are equivalent.”
- “Arthroscopic and open acromioplasty have equivalent ultimate clinical outcomes, operative times, and low complication rates.”
- “Intravenous immunoglobulin started within two weeks from onset hastens recovery as much as plasma exchange.”
- “From the evidence discussed, it is evident that oral topotecan has similar efficacy to IV topotecan [direct comparison] and CAV [indirect comparison].”

As demonstrated in the first example listed above, the conclusion statements of many of the reviews that used direct terms of EQ/NI contained hedging language such as “seems,” “suggests,” and “may.” In the remaining 31 reviews, the authors used less direct language to express what could be interpreted as a conclusion of equivalence. For example, in one review the authors concluded that “there was no difference in the hazard of death or recurrent myocardial infarction between patients treated with drug-eluting stents versus bare metal stents.”16

In another review the authors concluded that “there is no evidence that VATS [video assisted thoracoscopic surgery] is more effective than fibrinolytic treatment.”17

In only two reviews the authors indicated that their conclusions were supported by aspects of the strength of the evidence. In one review the authors reported that the conclusions drawn in their review were based on moderate quality evidence.18 The authors of the other review reported that their conclusion of equivalence between chest compressions-first versus defibrillation-first for out-of-hospital cardiac arrest was based on “no treatment effect with fairly narrow confidence intervals and with very little heterogeneity.”6 None of the reviews assessed in this document provided a rating of the strength of evidence.

## Summary

This document assessed current practices used within published systematic reviews that contain conclusions that could be interpreted as conclusions of equivalence or non-inferiority (EQ/NI) between two or more treatments. The information was intended to aid in the development of guidance for EPCs to follow when drawing conclusions of EQ/NI in the context of CERs. The focus of the document was on current practices within systematic reviews related to the following areas: assessing risk of bias, defining the minimum important difference (MID, or margin of EQ/NI), analytical basis for drawing conclusions of EQ/NI, and wording of conclusions of EQ/NI.

From a pool of 235 systematic reviews that met the inclusion criteria for this project, we randomly selected 50 for further review and data abstraction. We abstracted data related to the four areas listed above (See Table 1 for the full list of data abstracted from each review). Overall, none of the authors reported if any of the studies included in their review were designed to be EQ/NI trials. The majority of the authors reported using some method to assess the risk of bias or quality of the included studies. Many used a recognized method, instrument, or checklist to assess risk of bias, such as the Jadad scale, the method described in the Cochrane Handbook, and the Newcastle-Ottawa Quality Scale. A number of the factors assessed in the systematic reviews are likely to be important when assessing the risk of bias of studies that call themselves EQ/NI studies. These factors include: baseline comparability, blinding outcome assessors; completeness of data reporting, documentation of dropouts/lost to follow-up, and use of intention-to-treat analysis.

Table 1 Information abstracted from reviews

• | Background information on the reviews, including purpose, medical condition, interventions, and number and sample size of included trials
• | Methodological design of included studies, including if the included trials were designed to be EQ/NI trials or not
• | Primary/secondary outcomes
• | Internal validity of included studies
• | Definition of minimum important difference (MID), if used
• | Whether the MID was pre-specified
• | The use of meta-analysis to support the conclusion
• | Statistical methods used to perform meta-analysis, if conducted
• | Results of meta-analysis, including summary estimates and 95% confidence intervals when available
• | Authors’ conclusions
• | Categorization of conclusions (e.g., conclusion contains direct terms of EQ/NI such as the two treatments are “equivalent,” “similar,” or “not inferior” to each other)
• | Strength-of-evidence ratings, if used

The information described above is presented in detail in the data tables located in the Appendices of this document. The remainder of this document summarizes the information presented in the data tables.

In only three systematic reviews did the authors define an MID for some of the outcomes considered in their review. In all three reviews, the definition of MID used was pre-specified and based on previously published studies or reports. The authors of the reviews did not indicate that the MID defined in their review was to be used as a margin for determining if the treatments being evaluated were equivalent or not inferior to each other. However, in one review, the authors concluded that the treatments being evaluated appeared to be equivalent. This conclusion was based on the meta-analytic results of the review, which indicated no statistically or clinically significant difference between the treatments being compared.

In the majority of the reviews, the authors based their conclusions of EQ/NI on a statistically non-significant finding from meta-analyses. According to many of the regulatory documents reviewed in Methods Project 1, it is inappropriate to draw a conclusion of EQ/NI solely on the basis of a non-significant difference. Overall, 38 percent of the conclusion statements of the reviews assessed used direct terms of EQ/NI, such as “equivalent to,” “similar to,” “comparable to,” and “not inferior to.” In the remaining reviews, the authors used less direct language (e.g., “There is no difference [in outcomes] between patients treated with drug-eluting stents versus bare metal stents.”) to express what could be interpreted as a conclusion of equivalence. Finally, in only two reviews the authors indicated that their conclusions were supported by aspects of the strength of the evidence.

## Conclusion

This review underscores the need to develop guidance for EPCs to follow when drawing conclusions of equivalence or non-inferiority in the context of comparative effectiveness reviews. The results of our assessment suggest that authors of recently published systematic reviews do not always assess factors of risk of bias that may be important when drawing conclusions of EQ/NI, do not commonly define or use an MID (or margin of EQ/NI), and do not typically pre-specify how they will handle findings of no difference or similarity. In many of the reviews assessed in this document, meta-analytic findings of no statistically significant difference were interpreted as equivalence between two treatments. Thus, developing guidance on how and when it is appropriate to draw conclusions of equivalence or non-inferiority in the context of comparative effectiveness reviews would avoid confusion and misinterpretation of reports generated by EPCs.

## References

1 Yang Q, Xie DR, Jiang ZM, et al. Efficacy and adverse effects of transdermal fentanyl and sustained-release oral morphine in treating moderate-severe cancer pain in Chinese population: a systematic review and meta-analysis. J Exp Clin Cancer Res. 2010;29:67. [pmid: 20529380].
2 Kalil AC, Murthy MH, Hermsen ED, et al. Linezolid versus vancomycin or teicoplanin for nosocomial pneumonia: a systematic review and meta-analysis. Crit Care Med. Sep. 2010;38(9):1802-8. [pmid: 20639754].
3 Kesselheim AS, Stedman MR, Bubrick EJ, et al. Seizure outcomes following the use of generic versus brand-name antiepileptic drugs: a systematic review and meta-analysis. Drugs. Mar. 26. 2010;70(5):605-21. [pmid: 20329806].
4 Tang Y, Li X, Yin S. Outcomes of MTA as root-end filling in endodontic surgery: a systematic review. Quintessence Int. Jul–Aug. 2010;41(7):557-66. [pmid: 20614042].
5 Beauchamp MK, Nonoyama M, Goldstein RS, et al. Interval versus continuous training in individuals with chronic obstructive pulmonary disease--a systematic review. Thorax. Feb. 2010;65(2):157-64. [pmid: 19996334].
6 Meier P, Baker P, Jost D, et al. Chest compressions before defibrillation for out-of-hospital cardiac arrest: a meta-analysis of randomized controlled clinical trials. BMC Med. 2010;8:52. [pmid: 20828395].
7 Tamayo JM, Zarate CA Jr, Vieta E, et al. Level of response and safety of pharmacological monotherapy in the treatment of acute bipolar I disorder phases: a systematic review and meta-analysis. Int J Neuropsychopharmacol. Jul. 2010;13(6):813-32. [pmid: 20128953].
8 Riemsma R, Simons JP, Bashir Z, et al. Systematic Review of topotecan (Hycamtin) in relapsed small cell lung cancer. BMC Cancer. 2010;10:436. [pmid: 20716361].
9 Lanitis S, Tekkis PP, Sgourakis G, et al. Comparison of skin-sparing mastectomy versus non-skin-sparing mastectomy for breast cancer: a meta-analysis of observational studies. Ann Surg. Apr. 2010;251(4):632-9. [pmid: 20224371].
10 Vermeulen H, Westerbos SJ, Ubbink DT. Benefit and harm of iodine in wound care: a systematic review. J Hosp Infect. Nov. 2010;76(3):191-9. [pmid: 20619933].
11 Groeneveld AB, Navickis RJ, Wilkes MM. Update on the comparative safety of colloids: a systematic review of clinical studies. Ann Surg. Mar. 2011;253(3):470-83. [pmid: 21217516].
12 Squizzato A, Manfredi E, Bozzato S, et al. Antithrombotic and fibrinolytic drugs for retinal vein occlusion: a systematic review and a call for action. Thromb Haemost. Feb. 2010;103(2):271-6. [pmid: 20126837].
13 Loveman E, Jones J, Hartwell D, et al. The clinical effectiveness and cost-effectiveness of topotecan for small cell lung cancer: a systematic review and economic evaluation. Health Technol Assess. Mar. 2010;14(19):1-204. [pmid: 20356561].
14 Chua TC, Liauw W, Saxena A, et al. Systematic review of neoadjuvant transarterial chemoembolization for resectable hepatocellular carcinoma. Liver Int. Feb. 2010;30(2):166-74. [pmid: 19912531].
15 Vasiliadis HS, Wasiak J, Salanti G. Autologous chondrocyte implantation for the treatment of cartilage lesions of the knee: a systematic review of randomized studies. Knee Surg Sports Traumatol Arthrosc. Dec. 2010;18(12):1645-55. [pmid: 20127071].
16 Dibra A, Tiroch K, Schulz S, et al. Drug-eluting stents in acute myocardial infarction: updated meta-analysis of randomized trials. Clin Res Cardiol. Jun. 2010;99(6):345-57. [pmid: 20221617].
17 Krenke K, Peradzynska J, Lange J, et al. Local treatment of empyema in children: a systematic review of randomized controlled trials. Acta Paediatr. Oct. 2010;99(10):1449-53. [pmid: 20456264].
18 Dubicka B, Elvins R, Roberts C, et al. Combined treatment with cognitive-behavioural therapy in adolescent depression: meta-analysis. Br J Psychiatry. Dec. 2010;197:433-40. [pmid: 21119148].
19 Bodri D, Sunkara SK, Coomarasamy A. Gonadotropin-releasing hormone agonists versus antagonists for controlled ovarian hyperstimulation in oocyte donors: a systematic review and meta-analysis. Fertil Steril. Jan. 2011;95(1):164-9. [pmid: 20684954].
20 Greenhalgh J, Hockenhull J, Rao N, et al. Drug-eluting stents versus bare metal stents for angina or acute coronary syndromes. Cochrane Database Syst Rev. 2010;(5):CD004587. [pmid: 20464732].
21 Seitz DP, Adunuri N, Gill SS, et al. Antidepressants for agitation and psychosis in dementia. Cochrane Database Syst Rev. 2011;2:CD008191. [pmid: 21328305].
22 Davis AD, Kakar S, Moros C, et al. Arthroscopic versus open acromioplasty: a meta-analysis. Am J Sports Med. Mar. 2010;38(3):613-8. [pmid: 19188562].
23 Dong L, Zhang F, Shu X. Early administration of small-molecule glycoprotein IIb/IIIa inhibitors before primary percutaneous coronary intervention for ST-elevation myocardial infarction: insights from randomized clinical trials. J Cardiovasc Pharmacol Ther. Jun. 2010;15(2):135-44. [pmid: 20435991].
24 Dong L, Zhang F, Shu X. Upstream vs deferred administration of small-molecule glycoprotein IIb/IIIa inhibitors in primary percutaneous coronary intervention for ST-segment elevation myocardial infarction: insights from randomized clinical trials. Circ J. Aug. 2010;74(8):1617-24. [pmid: 20571247].
25 Fuentes JP, Armijo Olivo S, Magee DJ, et al. Effectiveness of interferential current therapy in the management of musculoskeletal pain: a systematic review and meta-analysis. Phys Ther. Sep. 2010;90(9):1219-38. [pmid: 20651012].
26 Wu H, Xu MJ, Zou DJ, et al. Intensive glycemic control and macrovascular events in type 2 diabetes mellitus: a meta-analysis of randomized controlled trials. Chin Med J (Engl). Oct. 2010;123(20):2908-13. [pmid: 21034605].
27 Hughes RA, Swan AV, van Doorn PA. Intravenous immunoglobulin for Guillain-Barre syndrome. Cochrane Database Syst Rev. 2010;(6):CD002063. [pmid: 20556755].
28 Myers J, Chan V, Jarvis V, et al. Intraspinal techniques for pain management in cancer patients: a systematic review. Support Care Cancer. Feb. 2010;18(2):137-49. [pmid: 19943068].
29 Lee YH, Woo JH, Choi SJ, et al. Induction and maintenance therapy for lupus nephritis: a systematic review and meta-analysis. Lupus. May. 2010;19(6):703-10. [pmid: 20064907].
30 Liu JG, Wang YJ, Du Z. Radiofrequency ablation in the treatment of small hepatocellular carcinoma: a meta analysis. World J Gastroenterol. Jul. 21. 2010;16(27):3450-6. [pmid: 20632451].
31 Liu Z, Zhang P, Ma Y, et al. Laparoscopy or not: a meta-analysis of the surgical effects of laparoscopic versus open appendectomy. Surg Laparosc Endosc Percutan Tech. Dec. 2010;20(6):362-70. [pmid: 21150411].
32 Zhang Y, Zhang P, Mu Y, et al. The role of renin-angiotensin system blockade therapy in the prevention of atrial fibrillation: a meta-analysis of randomized controlled trials. Clin Pharmacol Ther. Oct. 2010;88(4):521-31. [pmid: 20811347].
33 Wang X, Liu R, Ma B, et al. High dose rate versus low dose rate intracavity brachytherapy for locally advanced uterine cervix cancer. Cochrane Database Syst Rev. 2010;(7):CD007563. [pmid: 20614461].
34 Macedo LG, Smeets RJ, Maher CG, et al. Graded activity and graded exposure for persistent nonspecific low back pain: a systematic review. Phys Ther. Jun. 2010;90(6):860-79. [pmid: 20395306].
35 Machado M, Einarson TR. Comparison of SSRIs and SNRIs in major depressive disorder: a meta-analysis of head-to-head randomized clinical trials. J Clin Pharm Ther. Apr. 2010;35(2):177-88. [pmid: 20456736].
36 Milito G, Cadeddu F, Muzi MG, et al. Haemorrhoidectomy with Ligasure vs conventional excisional techniques: meta-analysis of randomized controlled trials. Colorectal Dis. Feb. 2010;12(2):85-93. [pmid: 19220374].
37 Murphy JD, Yan D, Hanna MN, et al. Comparison of the postoperative analgesic efficacy of intravenous patient-controlled analgesia with tramadol to intravenous patient-controlled analgesia with opioids. J Opioid Manag. Mar–Apr. 2010;6(2):141-7. [pmid: 20481179].
38 Pan XH, Chen YX, Xiang MX, et al. A meta-analysis of randomized trials on clinical outcomes of paclitaxel-eluting stents versus bare-metal stents in ST-segment elevation myocardial infarction patients. J Zhejiang Univ Sci B. Oct. 2010;11(10):754-61. [pmid: 20872982].
39 Sbruzzi G, Ribeiro RA, Schaan BD, et al. Functional electrical stimulation in the treatment of patients with chronic heart failure: a meta-analysis of randomized controlled trials. Eur J Cardiovasc Prev Rehabil. Jun. 2010;17(3):254-60. [pmid: 20560163].
40 Sgourakis G, Gockel I, Radtke A, et al. The use of self-expanding stents in esophageal and gastroesophageal junction cancer palliation: a meta-analysis and meta-regression analysis of outcomes. Dig Dis Sci. Nov. 2010;55(11):3018-30. [pmid: 20440646].
41 Simpson PM, Goodger MS, Bendall JC. Delayed versus immediate defibrillation for out-of-hospital cardiac arrest due to ventricular fibrillation: a systematic review and meta-analysis of randomised controlled trials. Resuscitation. Aug. 2010;81(8):925-31. [pmid: 20483525].
42 Sunkara SK, Siozos A, Bolton VN, et al. The influence of delayed blastocyst formation on the outcome of frozen-thawed blastocyst transfer: a systematic review and meta-analysis. Hum Reprod. Aug. 2010;25(8):1906-15. [pmid: 20542896].
43 Tamhane UU, Chetcuti S, Hameed I, et al. Safety and efficacy of thrombectomy in patients undergoing primary percutaneous coronary intervention for acute ST elevation MI: a meta-analysis of randomized controlled trials. BMC Cardiovasc Disord. 2010;10:10. [pmid: 20187958].
44 Testa L, Agostoni P, Vermeersch P, et al. Drug eluting stents versus bare metal stents in the treatment of saphenous vein graft disease: a systematic review and meta-analysis. EuroIntervention. Sep. 2010;6(4):527-36. [pmid: 20884442].
45 Valachis A, Mauri D, Polyzos NP, et al. Partial breast irradiation or whole breast radiotherapy for early breast cancer: a meta-analysis of randomized controlled trials. Breast J. May–Jun. 2010;16(3):245-51. [pmid: 20210799].
46 Xie X, Dendukuri N, McGregor M. Percutaneous radiofrequency ablation for the treatment of early stage hepatocellular carcinoma: a health technology assessment. Int J Technol Assess Health Care. Oct. 2010;26(4):390-7. [pmid: 20923590].
47 Agarwal S, Tuzcu EM, Desai MY, et al. Updated meta-analysis of septal alcohol ablation versus myectomy for hypertrophic cardiomyopathy. J Am Coll Cardiol. Feb. 23. 2010;55(8):823-34. [pmid: 20170823].
48 Avouac J, Vicaut E, Bardin T, et al. Efficacy of joint lavage in knee osteoarthritis: meta-analysis of randomized controlled studies. Rheumatology (Oxford). Feb. 2010;49(2):334-40. [pmid: 19955221].
49 Devaiah AK, Andreoli S. Postmaneuver restrictions in benign paroxysmal positional vertigo: an individual patient data meta-analysis. Otolaryngol Head Neck Surg. Feb. 2010;142(2):155-9. [pmid: 20115966].
50 Valachis A, Mauri D, Polyzos NP, et al. Fulvestrant in the treatment of advanced breast cancer: a systematic review and meta-analysis of randomized controlled trials. Crit Rev Oncol Hematol. Mar. 2010;73(3):220-7. [pmid: 19369092].

## Appendices

### Appendix A

Table 2 Characteristics of systematic reviews

### Appendix B

Table 3 Assessment of internal validity within systematic reviews

### Appendix C

Table 4 Method of defining MID within systematic reviews

Reference | MID Defined by Systematic Reviewers | Pre-specified by Reviewers | Range of MID Defined within Original Trials
Bodri et al. 2011 19 | No MID was defined or used | No | Not reported
Groeneveld et al. 2011 11 | No MID was defined or used | No | Not reported
Hockenhull et al. 2011 20 | No MID was defined or used | No | Not reported
Seitz et al. 2011 21 | No MID was defined or used | No | Not reported
Beauchamp et al. 2010 5 | 0.5 minimal important difference for the CRQ domains of dyspnea and total score, and 54 m for the 6 minute walk test (6MWT) | Yes | Not reported
Davis et al. 2010 22 | No MID was defined or used | No | Not reported
Dibra et al. 2010 16 | No MID was defined or used | No | Not reported
Dong et al. 2010 23 | No MID was defined or used | No | Not reported
Dong et al. 2010 24 | No MID was defined or used | No | Not reported
Dubicka et al. 2010 18 | No MID was defined or used | No | Not reported
Fuentes et al. 2010 25 | No MID was defined or used | No | Not reported
Hong et al. 2010 26 | No MID was defined or used | No | Not reported
Hughes et al. 2010 27 | No MID was defined or used | No | Not reported
Kalil et al. 2010 2 | No MID was defined or used | No | Not reported
Kesselheim et al. 2010 3 | No MID was defined or used | No | Not reported
Krenke et al. 2010 17 | No MID was defined or used | No | Not reported
Lanitis et al. 2010 28 | No MID was defined or used | No | Not reported
Lee et al. 2010 29 | No MID was defined or used | No | Not reported
Liu et al. 2010 30 | No MID was defined or used | No | Not reported
Liu et al. 2010 31 | No MID was defined or used | No | Not reported
Liu et al. 2010 32 | No MID was defined or used | No | Not reported
Liu et al. 2010 33 | No MID was defined or used | No | Not reported
Macedo et al. 2010 34 | No MID was defined or used | No | Not reported
Machado et al. 2010 35 | No MID was defined or used | No | Not reported
Meier et al. 2010 6 | The authors defined a “clinically relevant change for the primary outcome-survival to hospital discharge as a relative change of 20% to 25%.” | Yes | Not reported
Milito et al. 2010 36 | No MID was defined or used | No | Not reported
Murphy et al. 2010 37 | No MID was defined or used | No | Not reported
Myers et al. 2010 9 | No MID was defined or used | No | Not reported
Pan et al. 2010 38 | No MID was defined or used | No | Not reported
Riemsa et al. 2010 8 | No MID was defined or used | No | Not reported
Sbruzzi et al. 2010 39 | No MID was defined or used | No | Not reported
Sgourakis et al. 2010 40 | No MID was defined or used | No | Not reported
Simpson et al. 2010 41 | No MID was defined or used | No | Not reported
Squizzato et al. 2010 12 | No MID was defined or used | No | Not reported
Sunkara et al. 2010 42 | No MID was defined or used | No | Not reported
Tamayo et al. 2010 7 | Only NNTs or NNHs <10 are considered clinically meaningful | Yes | Not reported
Tamhane et al. 2010 43 | No MID was defined or used | No | Not reported
Tang et al. 2010 4 | No MID was defined or used | No | Not reported
Testa et al. 2010 44 | No MID was defined or used | No | Not reported
Valachis et al. 2010 45 | No MID was defined or used | No | Not reported
Vasiliadis et al. 2010 15 | No MID was defined or used | No | Not reported
Vermeulan et al. 2010 10 | No MID was defined or used | No | Not reported
Xie et al. 2010 46 | No MID was defined or used | No | Not reported
Yang et al. 2010 1 | No MID was defined or used | No | Not reported
Agarwal et al. 2010 47 | No MID was defined or used | No | Not reported
Avouac et al. 2010 48 | No MID was defined or used | No | Not reported
Chua et al. 2010 14 | No MID was defined or used | No | Not reported
Devaiah et al. 2010 49 | No MID was defined or used | No | Not reported
Loveman et al. 2010 13 | No MID was defined or used | No | Not reported
Valachis et al. 2010 50 | No MID was defined or used | No | Not reported

MID Minimal important difference

NNH Number needed to harm

NNT Number needed to treat

### Appendix D

Table 5 Methods used to draw conclusions within systematic review

### Appendix E

Table 6 Wording of conclusion