# Methods Project 1: Existing Guidance for Individual Trials

## Purpose

This document is intended to inform the development of EPC guidance on equivalence and non-inferiority. It summarizes publically available guidance (mostly from regulatory agencies) for individual trials that describe themselves as equivalence trials or non-inferiority trials. Thus, it will be most relevant to how EPCs might 1) adjust their risk-of-bias assessment methods when confronted with these types of trials, and 2) determine an appropriate reviewer threshold (such as the minimum important difference) for deciding whether the included evidence permits a conclusion of equivalence or non-inferiority within the context of systematic reviews.

## Methods

A searcher from the Scientific Resource Center (SRC) searched numerous sources for any formal guidance on the planning, conduct, analysis, and interpretation of clinical trials described as equivalence or non-inferiority (EQ-NI) trials. One reviewer (JRT) read through the search results for relevant guidance documents. The same reviewer read each relevant document in detail, capturing statements in five categories:

- Definitions/justifications/assumptions, including definitions of EQ-NI trials, appropriate justifications for their use, and assumptions made
- Planning EQ-NI trials, including pre-specification of trial intent, choice of control groups, threshold for decision making, and sample size calculations
- Conducting EQ-NI trials, particularly avoiding bias
- Analyzing EQ-NI trials, including the use of confidence intervals, the use of intention-to-treat or per-protocol analysis, one-tailed or two-tailed tests, and multiplicity
- Interpreting/reporting EQ-NI trials, including the types of permissible conclusions, the conditions under which the conclusion can differ from the original trial intent, and reporting requirements

## Results

### General description of guidance documents

Searches identified 14 potentially relevant documents, but two (one from Health Canada1 and one from the European Medicines Agency)2 were simply endorsements of one of the other documents.3 Thus, we extracted information from 12 documents. These included 10 documents from 6 regulatory groups, and two documents from collaborative academic groups:

- Two documents from the International Conference on Harmonisation (ICH) of Technical Requirements for Registration of Pharmaceuticals for Human Use: one in 1998,^3^ and one in 2000.^4^
- Four documents from European Medicines Agency (EMEA): two in 2000,^5,6^ one in 2003,^7^ and one in 2005.^8^
- A 2008 document from the Australian Pharmaceutical Benefits Advisory Committee (Australian PBAC) from 2008.^9^
- A 2008 document from the Japan Pharmaceuticals and Medical Devices Agency (Japan PMDA) from 2008.^10^
- A 2010 document from the U.S. Food and Drug Administration (FDA), in 2010.^11^
- A 2010 document from the India Central Drugs Standard Control Organisation (hereafter abbreviated India CDSCO) from 2010.^12^
- One document from Gomberg-Maitlin et al. (2003).13
- One document that was an extension of CONSORT guidelines, Piaggio et al. (2006).14

Appendix A (starting on page 14) provides the verbatim statements from the 12 documents, using the categories listed in the Methods section above.

Most of the documents were written from the perspective of regulatory agencies, therefore the primary focus was not on comparative effectiveness, but whether a given treatment can be judged as efficacious. To this extent, their usefulness in the context of comparativeness effectiveness may be limited. However, these types of trials involve active-treatment control groups, and such trials provide direct evidence comparing treatments, which is a major interest of comparative effectiveness research. This common thread means that many of regulatory statements can have implications for systematic reviews of comparative effectiveness, particularly in the areas of 1) determining the minimum important difference, 2) assessing unique sources of bias in these types of trials, and 3) drawing conclusions based on these trials.

### Definitions/Justification/Assumptions

The stated definitions of an “equivalence trial” were quite consistent (e.g., trials “designed to confirm the absence of a meaningful difference between treatments”).5 Regarding a “non-inferiority” trial, four documents3,5,9,14 contained statements that the intent was to show that “the proposed drug is no worse than its main comparator”9 (or used similar wording). Two documents,8,11 however, pointed out that technically, “only a superiority trial can demonstrate this”, because the exclusion of any possible inferiority logically requires a demonstration of superiority, and so the definition should include the idea that the intent is to show that the difference is not larger than some “pre-specified, small amount.”8

Two documents4,14 criticized the fact that some authors use the term equivalence trial to refer to what was actually a non-inferiority trial, and one document called the phrase “equivalence trial” a “misnomer, as true equivalence (i.e., assurance that the test drug is not any less effective than the control), could only be shown by demonstrating superiority.”11 This latter document appeared to argue against future use of the phrase “equivalence trial” for this reason.

Regarding valid justifications for performing EQ-NI trials, the documents cited four general reasons:

- Ethical problems with placebo-controlled trials and/or the existence of a proven treatment,11,13,14 (i.e., if an effective treatment exists, the key issue from a patient’s perspective is how the newer treatment compares to it, rather than whether a newer treatment works at all)
- Safety/cost/convenience advantages of the newer treatment that could counterbalance the reduced efficacy,8,13,14
- General interest in comparative efficacy or effectiveness,10,11 and
- Infeasibility of a superiority trial.4,8

Several documents4,11–13 stressed the importance of an underlying assumption of EQ-NI trials: that the active control treatment actually worked in the trial (e.g., by improving outcomes to the usual degree). This is a necessary assumption because if the active control treatment had not worked, then showing equivalence or noninferiority to it would not constitute evidence of efficacy of the new treatment being submitted for regulatory clearance. The relevant phrase “assay sensitivity” was used by some documents4,11,12 to denote the ability of a trial to distinguish efficacious from inefficacious treatments. A key component of assay sensitivity was a demonstration that the active control actually had its intended effect in the non-inferiority trial (possibly via comparison to data from prior studies).

### Planning

The importance of pre-specifying the intent of the trial was a common refrain.3,5,8,14 Some documents,5,11,13,14 however, did state that it can be quite appropriate to draw conclusions from a trial even when the trial was not designed for that conclusion (see details on this point in the section below on Interpreting/reporting). One document5 stated that the trial intent can be changed midstream, but optimally the trial would be designed with all reasonable possibilities in mind. This latter document provided conditions under which changes are acceptable. For example, switching from non-inferiority to superiority was generally more acceptable than the reverse; switching from superiority to non-inferiority would require prior specification of the non-inferiority margin.5

Regarding the types of control groups, six documents3,8,10,11,13 stated that ideally the trial would contain at least three arms: the reference treatment, the control treatment, and a placebo treatment. One stated that a control group may actually not be necessary.10 Several documents asserted the importance of using an appropriate drug for the active control treatment,3,10,11 and at the appropriate dose.4,9,10,13

Trials measure multiple outcomes, so an outstanding question is whether a trial’s initial intent applies to just the primary outcome, or to all outcomes. The two documents8,14 mentioning this issue agreed that trials can have different intentions for different outcomes, and that the research protocol would state for “which outcomes noninferiority or equivalence hypotheses apply and for which superiority hypotheses apply”.14

A priori power calculations utilizing the pre-specified threshold was mentioned by many documents,3,5,9,11,13,14 but the key focus was on producing a confidence interval sufficiently narrow to permit a conclusion, regardless of whether an a priori power calculation had been performed. One document stated that after a trial is complete, “power calculations are of relatively little interest”, because of the paramount importance of the post-trial confidence interval.5

The rest of this section is devoted to the threshold for decision making, which was referred to by the documents as the “margin” or “Δ” (delta). We first discuss the various definitions; then the importance of a priori specification; and finally the documents’ advice for determining/justifying the chosen threshold.

Various definitions of the threshold revealed a subtle difference in wording. The two journal publications13,14 described the threshold in terms of the smallest value that would be clinically important. Three regulatory documents3,5,11 described it as the largest difference that is clinically acceptable. The importance of this difference in perspective is unclear, and may be due to the differing informational foci of academic authors and regulatory agencies. The ICH E10 document did not take either of these perspectives, instead defining the threshold generically as “the degree of inferiority of the test treatments to the control that the trial will attempt to exclude statistically.”4 None of the documents clarified what was meant by the word “clinically”; whether this meant a difference that would be noticed by patients, or a difference that would be noticed by physicians, or a difference that would actually result in a change in clinical management, or a difference in other important outcomes, or other possible interpretations.

The documents agreed on the importance of a priori specification of the decision threshold, whatever its definition.3–5,7,8,10,11,13,14 The rationale is clear: post-hoc specification leaves “ample room for bias.”5 Specifically, if a researcher can choose the decision threshold after analyzing the data, then the researcher might choose it in such a way to bolster his own interpretation of the data. Of course, this post-hoc activity would not at all influence the actual data, but would influence the author’s personal interpretation of the data.

Definitions and timing aside, the documents consistently acknowledged the difficulty faced by researchers in determining and justifying the chosen threshold. Mention of a focus on “clinical” impact was common,3,4,8,9,11,13,14 but again it was unclear what exactly was meant by “clinical.” Some mentioned that “statistical” considerations play a role in determining the threshold.4,8,11 Other influencing factors mentioned included how well the active-control treatment works,4,11,13 historical data,4 safety,14 cost,14 acceptability,14 adherence,14 independent expert consensus,13 and regulatory requirements.13 One document8 specifically stated that the choice of threshold should not be influenced by the anticipated sample size (because of the obvious bias). The documents were consistent in recommending that research justify the chosen threshold.3,4,8,9,11–14

Several specific statements were made about whether the threshold should be on a relative scale (e.g., relative risk or odds ratio) or an absolute scale (e.g., rate difference). One recommended the use of a relative scale,13 another recommended that researchers can use either,14 another recommended that they use both.9 For continuous measures, one document8 specifically recommended against the use of the standardized mean difference as the metric for the threshold. The reason was that “this statistic provides information on how difficult a difference would be to detect, but does not help justify the clinical relevance of the difference, and does not ensure that the test product is superior to placebo”.8

Two documents disagreed on the appropriateness of the following strategy for setting the threshold. The FDA document11 recommended that the researcher first set the value for M1, defined as “treatment effect of the active comparator” (i.e., how well the active control treatment is expected to work), and second define the value for M2, defined as the critical decision threshold for the non-inferiority trial, “by taking a percentage or fraction of M1.”11 For example, “A typical value for M2 is often 50% of M1, at least partly because the sample sizes needed to rule out a smaller loss become impractically large.”11 One of the EMEA documents,8 however, recommended against this overall approach, stating:

“It is not appropriate to define the non-inferiority margin as a proportion of the difference between active comparator and placebo. Such ideas were formulated with the aim of ensuring that the test product was superior to (a putative) placebo; however they may not achieve this purpose. If the reference product has a large advantage over placebo this does not mean that large differences are unimportant, it just means that the reference product is very efficacious”8

### Conducting

In this section, we list the unique aspects of risk-of-bias that, according to the reviewed documents, require particular attention in trials that define themselves as EQ-NI trials. In superiority trials, poor conduct tends to preclude any conclusion of superiority. But in EQ-NI trials, the documents agreed that a sloppily-run trial can actually bolster an incorrect conclusion of EQ or NI; if the trial had been better conducted, an important difference might have been observed. Below are the nine specific potential sources of bias mentioned:

- PATIENTS
  ○ Vague or inconsistently applied patient enrollment criteria or diagnostic criteria3–5,11
  ○ Patients selected for anticipated nonresponse or relatively high response rate4,14
- TREATMENTS
  ○ Poor compliance with treatments3,4,11,14
  ○ Concomitant treatments that mask true differences by producing a ceiling effect4,11,13
  ○ Inappropriate dosing4,9,13
  ○ Patients did not receive the treatment as assigned, or patients crossed over to the other treatment5,11,14
- MEASUREMENT
  ○ Dropouts3,4,11,14
  ○ Inadequate outcome measurement techniques5,11
  ○ Outcome assessor bias because they know that all groups received active treatment4,11

Many of the above sources of risk-of-bias also apply to trials that call themselves superiority trials. Below, Table 1 places each of these nine issues according to this concern as well as whether the potential would tend to lead to underestimates or overestimates (or both) of the difference between groups. We suspect that six of the nine issues could lead to either overestimates or underestimates. Further, it seems that all of these risk-of-bias issues would also be potential concerns in trials that call themselves superiority trials.

Table 1 Risk of bias issues mentioned in the documents

Issue | Would this tend to lead to underestimates or overestimates of the difference between groups? | For SUPERIORITY trials, is this also a potential source of bias? | Comments
Vague or inconsistently applied patient enrollment criteria or diagnostic criteria | Over or under | Yes | This adds noise to the data.
Patients selected for anticipated nonresponse or high response | Under | Yes | This would result in an underestimate of the difference between groups, regardless of the trial intent: If patients are selected for anticipated nonresponse, then both treatments will appear ineffective, or if patients are selected for anticipated high response, then both treatments will appear effective.
Poor compliance | Over or under | Yes | If compliance is consistently poor, the difference would be underestimated. If compliance varies by treatment, the difference would be overestimated.
Concomitant treatments mask true differences | Under | Yes | In a superiority trial, this could result in a nonsignificant difference, even if the treatments truly differ
Inappropriate dosing | Over or under | Yes | The impact depends on whether dosing was too high or too low, and whether it was inappropriate in the same way for both groups
Patients did not receive the treatment as assigned, or patients crossed over to the other treatment | Under | Yes | In a superiority trial, this could result in a nonsignificant difference, even if the treatments truly differ
Dropouts | Over or under | Yes | The impact depends on whether dropouts were more common in one group than the other, and also the reasons for dropouts.
Inadequate outcome measurement techniques | Over or under | Yes | This would adds noise to the data.
Outcome assessor bias | Over or under | Yes | If assessors believe a priori that one treatment is better, then unblinded outcome measurement will be biased accordingly, regardless of the trial intent.

### Analyzing

Several documents agreed that researchers should not solely rely on intention-to-treat analysis in EQ-NI trials.3,5,9,11,13,14 The reason is that ITT analyses have the potential to obscure real differences between treatments. Instead they recommend that EQ-NI trials perform both intention-to-treat analysis and per-protocol analysis.3,5,9,11,13,14 Ideally, the results of these two analyses would indicate the same conclusion (or lack thereof). If they disagree, one document instructed researchers to use the one that provided the “least positive” results.13

There was wide agreement that researchers should compute 95% confidence intervals (CI) around the difference between groups, instead of simply computing p values.3,5–11,13,14 Some of the reasons provided were that the CI:

- “provides more information”,13
- is the “most straightforward”,5 and
- “because the CI not only evaluates the null hypothesis but indicates the effect size and the lower and upper bounds of the this estimate”.13

On whether to compute a one-tailed or two-tailed confidence interval in a non-inferiority trial, there was some disagreement among the documents. Two stated that one-sided comparisons should be used,3,13 but these did not specify whether the interval should be 95% one-sided or 97.5% one-sided. Two other documents5,11 argued for “two-sided 95% confidence intervals are to be used for all clinical trials whatever their objective.”5 The stated reason was “preserved consistency between significance testing and subsequent estimation …” If one-sided intervals are used, then they should be used with a coverage probability of 97.5%”.5 A fifth document14 took a more middle-ground approach, suggesting that “2-sided CIs are appropriate in most noninferiority trials. If a 1-sided 5% significance level is deemed acceptable for the noninferiority hypothesis test (a decision open to question), a 90% 2-sided CI could then be used.”14

Regarding multiplicity (i.e., statistical tests of multiple outcomes inflating the overall Type I error rate), one document11 advocated statistical adjustment in order to preserve the overall Type I error rate at 5%.

### Interpreting/Reporting

Three documents specifically stated that it would be inappropriate to draw a conclusion of equivalence or noninferiority solely on the basis of a non-significant difference.3,9,13 The obvious reason is that a non-significant difference alone does not discriminate between two very different situations: 1) when the confidence interval is narrow enough to exclude the possibility of a meaningful difference, and 2) when the confidence interval is too wide to permit any conclusion about whether the treatments differed.

Several documents discussed the possibility of drawing a type of conclusion that was not originally intended in the design of the trial:

- Agreement among four documents5,11,13,14 that it can be perfectly appropriate to draw a conclusion of superiority from a non-inferiority study, and two further stated that this situation requires no adjustment for multiplicity.5,11 One document13 made the additional point that the study must first establish non-inferiority before attempting to show superiority.
- Disagreement about the reasonableness of concluding equivalence from a superiority trial.11,13 One document essentially said that this would be inappropriate,13 but another11 said that this would occur “only rarely,” and the document outlined a specific example.
- Disagreement about the reasonableness of concluding non-inferiority from a superiority trial. Two documents said this can be acceptable if the decision threshold was pre-specified.5,14 A third, however, stated that “Seeking an NI conclusion in the event of a failed superiority test would almost never be acceptable …. If it is clear that an NI conclusion is a possibility, the study should be designed as an NI study.”11

The two academic papers listed several items that should be reported by studies calling themselves EQ or NI. Six items were listed by Gomberg-Maitlin et al. (2003)13 listed six items, and 22 by Piaggio et al. (2006)14 listed 22 items. Similarities were found between items 1–4 on the listed by Gomberg-Maitlin et al. (2003)13 and items 3, 7, and 13 by Piaggio et al. (2006)14. The other two items listed by, Gomberg-Maitlin et al.(2003)13 did not explicitly appear in the list by Piaggio et al. (2006).14 These involved specifying the “minimum requisite number of primary events” and “a comparison of event rates during treatment with the active control in the trial and in the historical trials that established its efficacy compared with placebo.” Piaggio et al. (2006)14 listed numerous additional detailed items that were not listed by Gomberg-Maitlin et al. (2003)13 (the full list of items appears in Appendix A).

## Summary

For the development of EPC guidance on equivalence and non-inferiority in the context of systematic reviews, the three most important aspects of this methods project are: 1) the various justifications for performing these kinds of trials; 2) strategies for determining the threshold for decision-making; and 3) the unique areas of potential bias in trials that call themselves EQ-NI. We next discuss these three areas.

The four justifications included ethical problems with placebo-controlled trials and/or the existence of a proven treatment, safety/cost/convenience advantages of the newer treatment that could counterbalance the reduced efficacy, a general interest in comparative efficacy or effectiveness, and the infeasibility of a superiority trial. These ideas could assist systematic reviewers in devising the Key Questions (including items in PICOTS), and/or the study inclusion criteria.

The documents consistently acknowledged the difficulty faced by researchers in determining the chosen threshold. The guidance was limited to generalities about what to consider when determining the threshold, and systematic reviewers might use these to determine what threshold(s) the review will employ. The documents consistently mentioned the need to focus on “clinical” impact, but the specific meaning of this was unclear. Additional influencing factors included statistical considerations, how well the active-control treatment works, historical data, safety, cost, acceptability, adherence, independent expert consensus, and regulatory requirements. One benefit of the reviewer deciding the threshold(s) to be used for analysis is that interpretation of the conclusiveness of the data (based on confidence intervals) would be more straightforward. The documents were consistent in recommending that the researcher justify the chosen threshold (as well as that it should be chosen a priori), and these recommendations also seem to apply to thresholds chosen by systematic reviewers.

Regarding risk-of-bias, the documents mentioned nine areas that can contribute to underestimates of the difference between active treatments. Most of these areas can also contribute to overestimates, depending on the specifics of the situation. Further, almost all of the nine areas would also be potential sources of bias in trials that call themselves superiority trials.

Finally, we note that most of these documents originated from regulatory agencies, and such agencies have different informational needs than systematic reviewers. Systematic reviewers are concerned about any direction of bias, whereas regulatory agencies are primarily concerned about bias in favor of the sponsor’s product. In the context of an EQ or NI trial, this bias can act to produce an incorrect conclusion of EQ or NI, when in fact there is a meaningful difference between the treatments being compared. This is evidenced in the regulatory focus on minimizing the chance of a type I error, since from a regulatory perspective that would involve providing marketing clearance for an inefficacious drug or device. Systematic reviewers, on the other hand, aim for the best possible estimate of the extent to which two treatments yield different outcomes: too-low estimates of this difference are just as bad as too-high estimates.

A second area of difference involves the fact that regulatory agencies tend to assume that a trial should stand on its own to demonstrate a finding, whereas systematic reviewers view a trial as one in a larger set of trials that, taken together, may or may not demonstrate a consistent finding. This is evident from the regulatory focus on whether a given trial has “assay sensitivity”. The regulatory decision is often based on one or two trials conducted by a single sponsor, whereas systematic reviewers typically review evidence from many different groups. An outgrowth of this difference in perspective involves meta-analysis, which is common among systematic reviews but relatively rare in analyses used by regulatory agencies. Meta-analysis often involves the calculation of effect sizes from reported information, which means that authors’ choices in interpreting and summarizing data are relatively unimportant, as long as the necessary underlying information is reported. For example, whether the author chose to perform both intention-to-treat analysis and per-protocol analysis is moot if they reported the underlying data necessary for a reviewer to perform the correct analyses. Also moot is whether the author deemed the evidence conclusive, as long as they reported their data sufficiently.

A third area involves differential interest in the generalizability or applicability of findings. This is important to any investigation of comparative “effectiveness,” but a regulatory agency is more focused on a proof of biological impact rather than whether this impact has been realized in multiple populations or multiple settings.

## References

1 Drugs and health products: ICH. [internet]. Ottawa (ON). Health Canada. Feb. 15. accessed 2011 May 19. 2011:1. Available: http://www.hc-sc.gc.ca/dhp-mps/prodpharma/applic-demande/guide-ld/ich/index-eng.php.
2 Committee for Proprietary Medicinal Products (CPMP). Note for guidance on statistical principles for clinical trials. London (UK). European Medicines Agency (EMEA). Sep. 1998:37. Also available: http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500002928.pdf.
3 ICH Expert Working Group. ICH harmonised tripartite guideline: statistical principles for clinical trials. Geneva. International Conference on Harmonisation (ICH). Feb. 5. 1998:39. Also available: http://www.ich.org/fileadmin/Public_Web_Site/ICH_Products/Guidelines/Efficacy/E9/Step4/E9_Guideline.pdf.
4 Committee for Proprietary Medicinal Products (CPMP). ICH topic E 10: choice of control group in clinical trials. London (UK). European Medicines Agency (EMEA). Jan. 2001:30.
5 Committee for Proprietary Medicinal Products (CPMP). Points to consider on switching between superiority and non-inferiority. London (UK). European Medicines Agency (EMEA). Jul. 27. 2000:11. Also available: http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003658.pdf.
6 Committee for Proprietary Medicinal Products (CPMP). Note for guidance on the investigation of bioavailability and bioequivalence. London (UK). European Medicines Agency (EMEA). Dec. 14. 2000:19.
7 Committee for Proprietary Medicinal Products (CPMP). Common technical document for the registration of pharmaceuticals for human use, Clinical overview and clinical summary of module 2. Module 5: study reports. London (UK). European Medicines Agency (EMEA). Jul. 2003:44. Also available: http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500002723.pdf.
8 Committee for Proprietary Medicinal Products (CPMP). Guideline on the choice of the non-inferiority margin. London (UK). European Medicines Agency (EMEA). Jul. 27. 2005:11. Also available: http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003636.pdf.
9 Pharmaceutical Benefits Advisory Committee. Guidelines for preparing submissions to the Pharmaceutical Benefits Advisory Committee (Version 4.3). Barton ACT. Commonwealth of Australia. Dec. 2008:300. Also available: http://www.pbs.gov.au/industry/listing/elements/pbac-guidelines/PBAC4.3.2.pdf.
10 Points to be considered by the review staff involved in the evaluation process of new drug. Final. Tokyo, Japan. Pharmaceuticals and Medical Devices Agency (PMDA). Apr. 17. 2008:6. Also available: http://www.pmda.go.jp/english/service/pdf/points.pdf.
11 Center for Drug Evaluation and Research (CDER), Center for Biologics Evaluation and Research (CBER). Guidance for industry: non-inferiority clinical trials. Rockville (MD). U.S. Food and Drug Administration (FDA). Mar. 2010:66. Also available: http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM202140.pdf.
12 Guidance for industry on preparation of common technical document for import / manufacture and marketing approval of new drugs for human use (New Drug Application – NDA). New Delhi. Central Drugs Standard Control Organization (CDSCO). Nov. 2010:110. Also available: http://cdsco.nic.in/CTD_Guidance%20-Final.pdf.
13 Gomberg-Maitland M, Frison L, Halperin JL. Active-control clinical trials to establish equivalence or noninferiority: methodological and statistical concepts linked to quality. Am Heart J. Sep. 2003;146(3):398-403. [pmid: 12947355].
14 Piaggio G, Elbourne DR, Altman DG, et al. Reporting of noninferiority and equivalence randomized trials: an extension of the CONSORT statement. JAMA. Mar. 8. 2006;295(10):1152-60. [pmid: 16522836].

## Appendix A

This appendix contains verbatim quotations from the source documents that were reviewed. These quotations were selected for the degree of relevance to the EPC workgroup on equivalence and non-inferiority, and they are not intended to be an exhaustive representation of the content of the source documents.

### Definitions/Justifications/Assumptions

#### Definitions of Equivalence Trial

“Although there is some variability in the definitions, equivalence trials are based on an active control, aiming to match the action of an established therapy and prove this to statistical significance within a predetermined range (Δ) in both positive and negative directions (a 2-sided test).”13

“An equivalence trial is designed to confirm the absence of a meaningful difference between treatments.”5

“…equivalence trials aim to determine whether one (typically new) intervention is therapeutically similar to another, usually an existing treatment.”14

Equivalence trial: “A trial with the primary objective of showing that the response to two or more treatments differs by an amount which is clinically unimportant. This is usually demonstrated by showing that the true treatment difference is likely to lie between a lower and an upper equivalence margin of clinically acceptable differences.”3

Therapeutic equivalence: “A medicinal product is therapeutically equivalence with another product if it contains the same active substance or therapeutic moiety and, clinically, shows the same efficacy and safety as that product, whose efficacy and safety have been established.”6

#### Definitions of Non-inferiority Trial

“In these [non-inferiority trials] we wish to show that a new treatment is no less effective than an existing treatment – it may be more effective or it may have a similar effect.“5

“A noninferiority trial seeks to determine whether a new treatment is no worse than a reference treatment.”14

“Noninferiority means that, in terms of effectiveness, the proposed drug is no worse than its main comparator.”9

Noninferiority trial: “A trial with the primary objective of showing that the response to the investigational product is not clinically inferior to a comparative agent (active or placebo control).”3

“Many active control trials are designed to show that the efficacy of an investigational product is no worse than that of the active comparator, and hence fall into the latter category [of non-inferiority trials].”3

“The term ‘non-inferiority’ is now well established, but if taken literally could be misleading. The objective of a non-inferiority trial is sometimes stated as being to demonstrate that the test product is not inferior to the comparator. However, only a superiority trial can demonstrate this. In fact a noninferiority trial aims to demonstrate that the test product is not worse than the comparator by more than a pre-specified, small amount.”8

“What non-inferiority trials seek to show is that any difference between the two treatments is small enough to allow a conclusion that the new drug has at least some effect or, in many cases, an effect that is not too much smaller than the active control.”11

#### Confusion Among Terms

“Not all noninferiority or equivalence trials use these words, and the term equivalence is often inappropriately used when reporting negative results of superiority trials; such trials often lack statistical power to rule out important differences. Identifying noninferiority trials is difficult because they are often labeled as equivalence trials.”14

“Clinical trials designed to demonstrate efficacy of a new drug by showing that it is similar in efficacy to a standard agent have been called “equivalence” trials. Most of these are actually non-inferiority trials, attempting to show that the new drug is not less effective than the control by more than a defined amount, generally called the margin”.4

“These active control trials, which are not intended to show superiority of the test drug, but to show that the new treatment is not inferior to an unacceptable extent, were once called equivalence trials, but this is a misnomer, as true equivalence (i.e., assurance that the test drug is not any less effective than the control), could only be shown by demonstrating superiority. Because the intent of the trial is one-sided (i.e., to show that the new drug is not materially worse than the control), they are now called non-inferiority (NI) trials. But that too, is a misnomer, as guaranteeing that the test drug is not any (even a little) less effective than the control can only be demonstrated by showing that the test drug is superior. What non-inferiority trials seek to show is that any difference between the two treatments is small enough to allow a conclusion that the new drug has at least some effect or, in many cases, an effect that is not too much smaller than the active control.”11

#### Justification

“Efficacy comparable to the standard strategy may be sufficient to justify the alternative when an advantage in safety, cost, or convenience is demonstrated (Figure 1).”13

“…equivalence and noninferiority trials should only be undertaken when a well-proven standard therapy exists”13

“Noninferiority trials are intended to show whether a new treatment has at least as much efficacy as the standard or is worse by an amount less than Δ, often on the premise that it has some other advantage, eg, greater availability, reduced cost, less invasiveness, fewer side effects (harms), or greater ease of administration, for instance, one daily dose rather than 2 doses or more than 2 doses.”14

“A noninferiority or equivalence trial requires that the reference treatment’s efficacy is established or is in widespread use so that a placebo or untreated control group would be deemed unethical.”14

“Evidence for other advantages of the new treatment over the reference treatment, if present, should be given, to justify use of the new treatment, if not inferior”14

“When the superiority of a drug is confirmed over placebo, a non-inferiority study with existing drugs may not always be necessary. However, if the clinical significance of a drug is unclear, even in the case when a standard drug has already been established for the indicated disease and the superiority of drug against placebo has been confirmed, it may be appropriate to conduct a non-inferiority study in order to clarify the clinical positioning of a drug with respect to the standard drug (e.g., anti-infective drugs, etc.). Additionally, to clarify the positioning of a drug with respect to the existing drugs, a controlled study with 3 groups including placebo, the investigational drug, and an existing drug as the control drug, may be useful, even if statistical power is not secured.”10

“In most cases, evidence of efficacy is most convincingly demonstrated by showing superiority to a concurrent control treatment. If a superiority trial is not feasible or is inappropriate for ethical or practical reasons, and if a defined treatment effect of the active control is regularly seen (e.g., as it is for antibiotics in most situations), a non-inferiority or equivalence trial can be used and can be persuasive.”4

“There are many situations where a non-inferiority trial might be performed as opposed to, or in addition to, a superiority trial over placebo. These include: • Applications based upon essential similarity in areas where bioequivalence studies are not possible, e.g. modified release products or topical preparations; • Products with a potential safety advantage over the standard might require an efficacy comparison to the standard to allow a risk-benefit assessment to be made; • Cases where a direct comparison against the active comparator is needed to help assess riskbenefit; • Cases where no important loss of efficacy compared to the active comparator would be acceptable; • Disease areas where the use of a placebo arm is not possible and an active control trial is used to demonstrate the efficacy of the test product. In the final 4 situations above a non-inferiority trial would not be necessary if superiority could be shown over the reference product.”8

“The usual reason for using a non-inferiority active control study design instead of a study design having more readily interpretable results (i.e., a superiority trial) is an ethical one. Specifically, this design is chosen when it would not be ethical to use a placebo, or a treatment control, or a very low dose of an active drug, because there is an effective treatment that provides an important benefit (e.g., life-saving or preventing irreversible injury) available to patients for the condition to be studied in the trial…. There are, however, other reasons for using an active control: (1) interest in comparative effectiveness and (2) assessing the adequacy (assay sensitivity) of a placebo-controlled study.”11

“If the comparator was suitable for a demonstration of non-inferiority, then there should be well-controlled data to show that it is an effective treatment.”5

#### Assumptions

“Equivalence and noninferiority trials rely on the premises that the superior efficacy of the active control over placebo has been previously proven for a given indication, and that this efficacy will be preserved under the conditions of the trial”13

“Assay sensitivity is a property of a clinical trial defined as the ability to distinguish an effective treatment from a less effective or ineffective treatment. Assay sensitivity is important in any trial but has different implications for trials intended to show differences between treatments (superiority trials) and trials intended to show non-inferiority. If a trial intended to demonstrate efficacy by showing superiority of a test treatment to control lacks assay sensitivity, it will fail to show that the test treatment is superior and will fail to lead to a conclusion of efficacy. In contrast, if a trial is intended to demonstrate efficacy by showing a test treatment to be non-inferior to an active control, but lacks assay sensitivity, the trial may find an ineffective treatment to be non-inferior and could lead to an erroneous conclusion of efficacy.”4

“…the NI [non-inferiority] study is dependent on knowing something that is not measured in the study, namely, that the active control had its expected effect in the NI study. This is critical to knowing that the trial had assay sensitivity (i.e., could have distinguished an effective from an ineffective drug). A successful superiority trial has, by definition, assay sensitivity. A “successful” NI trial, one that shows what appears to be an acceptably small difference between treatments, may or may not have had assay sensitivity and may or may not have supported a conclusion that the test drug was effective. Thus, if the active control had no effect at all in the NI trial (i.e., did not have any of its expected effect), then finding even a very small difference between control and test drug is meaningless, providing no evidence that the test drug is effective. Knowing whether the trial had assay sensitivity relies heavily on external (not within-study) information, giving NI studies some of the characteristics of a historical control trial.”11

“For non-inferiority trials used to demonstrate efficacy, the evidence supporting a determination that the trial had assay sensitivity and justifying the choice of non-inferiority margin.”12

“For non-inferiority trials used to demonstrate efficacy, the evidence supporting a determination that the trial had assay sensitivity and justifying the choice of non-inferiority margin.”12

The Japan PMDA10 stated that regulators should determine an answer to the question “Even though non-inferiority has been confirmed, has superiority to placebo been denied in other clinical studies?.”10

“If someone proposing to use an active-control or non-inferiority design cannot provide sufficient support for historical evidence of the sensitivity to drug effects of the study with the chosen non-inferiority margin, a finding of non-inferiority cannot be considered informative with respect to efficacy”4

“Lack of appropriate use of the control treatment would also make the study unusable as a non-inferiority study, if superiority of the test drug is not shown, because assay sensitivity of the study would not be ensured (see section 1.5.2).”4

“There are circumstances in which a finding of non-inferiority cannot be interpreted as evidence of efficacy. Specifically, for a finding of non-inferiority to be interpreted as showing efficacy, the trial needs to have had the ability to distinguish effective from less effective or ineffective treatments.”4

### Planning

#### Prespecifying the Trial Intent

“It is important to classify the therapeutic profile of the proposed drug in relation to its main comparator (ie whether it is therapeutically superior, inferior or equivalent to the comparator).”9

“Pre-definition of a trial as a superiority trial, an equivalence trial or a non-inferiority trial is necessary for numerous reasons including the following: to ensure that comparator treatments, doses, patient populations and endpoints are appropriate; to allow sample size estimates to be based on the correct power calculations; to ensure that equivalence and non-inferiority criteria are pre-defined; to permit appropriate analysis plans to be described in the protocol; to ensure that the trial has sufficient sensitivity to achieve its objectives.”5

Piaggio et al. (2006)14 listed one required reporting item “5. Specific objectives and hypotheses, including the hypothesis concerning noninferiority or equivalence.”14

“It is vital that the protocol of a trial design to demonstrate equivalence or non-inferiority contain a clear statement that this is its explicit intention.”3

#### Switching the Trial Intent

“Switching the objective of a trial from non-inferiority to superiority is feasible provided: the trial has been properly designed and carried out in accordance with the strict requirements of a non-inferiority trial; actual p-values for superiority are presented to allow independent assessment of the strength of the evidence; analysis according to the intention-to-treat principle is given greatest emphasis.”5

“Switching the objective of a trial from superiority to non-inferiority may be feasible provided: the non-inferiority margin with respect to the control treatment was pre-defined or can be justified (the latter is likely to prove difficult and to be limited to rare cases where there is a widely accepted value for Δ); analysis according to the intention-to-treat principle and PP [per protocol] analysis, showing confidence intervals and p-values for the null hypothesis of inferiority, give similar findings; the trial was properly designed and carried out in accordance with the strict requirements of a non-inferiority trial; the sensitivity of the trial is high enough to ensure that it is capable of detecting relevant differences if they exist; there is direct or indirect evidence that the control treatment is showing its usual level of efficacy.”5

“The problem of switching objectives post hoc can be avoided by designing a trial prospectively in the knowledge that both non-inferiority and superiority are outcomes of potential value.”5

“For a well-designed and conducted trial, there are few difficulties connected with the change from non-inferiority to superiority that cannot be addressed by appropriate analysis. However, there are more severe difficulties associated with the switch from superiority to non-inferiority because of the possible need to find a basis for, and agree on, a margin of equivalence after seeing the outcome, and because of the inherent difficulties of non-inferiority trials.”5

#### Inclusion of a Placebo Group

“A trial with 3 arms (one of which involves administration of a placebo) increases both the complexity and the sample size requirement, and may not be ethical when a superior treatment strategy has been established. However, if it is feasible, it allows the investigators, by use of regression analyses, to compare the investigative agent and active control individually to placebo and compare the investigative agent to active control. Hence equivalence or noninferiority trials can only be undertaken where a predictable control is accepted as the standard of care”13

“Where comparative effectiveness is the principal interest, it is usually important—where it is ethical, as would be the case in most symptomatic conditions—to include a placebo control as well as the active control. Trials of most symptomatic treatments have a significant failure rate (i.e., they often cannot show the drug is superior to placebo). Where that is the case in a comparative trial, seeing no difference between treatments is uninformative. Inclusion of a placebo group can provide clear evidence that the study did have assay sensitivity (the ability to distinguish effective from ineffective treatments), critical if a finding of no difference between treatments is to be interpretable. For example, we have seen that approximately 50% of all placebo-controlled antidepressant trials of effective agents cannot distinguish drug from placebo. A trial in which two antidepressants are compared and found to have a similar effect is informative only if we know that the two drugs can be distinguished from the concurrent placebo group.”11

“When the superiority of a drug is confirmed over placebo, a non-inferiority study with existing drugs may not always be necessary. However, if the clinical significance of a drug is unclear, even in the case when a standard drug has already been established for the indicated disease and the superiority of drug against placebo has been confirmed, it may be appropriate to conduct a non-inferiority study in order to clarify the clinical positioning of a drug with respect to the standard drug (e.g., anti-infective drugs, etc.). Additionally, to clarify the positioning of a drug with respect to the existing drugs, a controlled study with 3 groups including placebo, the investigational drug, and an existing drug as the control drug, may be useful, even if statistical power is not secured.”10

“Active control equivalence or non-inferiority trials may also incorporate a placebo, thus pursuing multiple goals in one trial; for example, they may establish superiority to placebo and hence validate the trial design and simultaneously evaluate the degree of similarity of efficacy and safety to the active comparator. There are well-known difficulties associated with the use of the active control equivalence (or non-inferiority) trials that do not incorporate a placebo or do not use multiple doses of the new drug. These relate to the implicit lack of any measure of internal validity (in contrast to superiority trials), thus making external validation necessary.”3

“A three-armed trial with test, reference and placebo allows some within-trial validation of the choice of non-inferiority margin and is therefore the recommended design; it should be used wherever possible”8

“Even where it would be ethical to include a placebo group in addition to the active treatments (e.g., in studies of a symptomatic treatment), one is not necessarily included in these comparative trials. Such omission of a placebo group may render such studies uninformative, however, when they show no difference between treatments, unless assay sensitivity can be supported in some other way.”11

#### Choice of Active Control Treatment

“In a disease area where the placebo responder rate is presumed to be constant, results showing the investigational drug’s non-inferiority against an existing drug or results from an objective and appropriate clinical study even without a control group may be sufficient for the evaluation.”10

The Japan PMDA10 stated that for showing non-inferiority/superiority against an active control, regulators should determine answers to the questions “Is the control drug appropriate?” and “Is the dosage of the control drug appropriate?”10

“Active comparators should be chosen with care. An example of a suitable active comparator would be a widely used therapy whose efficacy in the relevant indication has been clearly established and quantified in well designed and well documented superiority trial(s) and which can be reliably expected to exhibit similar efficacy in the contemplated active control trial.”3

“In practice, an active control equivalence or non-inferiority trial offered as evidence of efficacy also almost always needs to provide a fair effectiveness comparison with the control, because any doubt as to whether the control in the study had its usual effect would undermine assurance that the trial had assay sensitivity (see section 1.5). Among aspects of trial design that could unfairly favor one treatment are choice of dose or patient population and selection and timing of endpoints”.4

“The active control must be a drug whose effect is well-defined. The most obvious choice is the drug used in the historical placebo-controlled trials. Where studies of several pharmacologically similar drugs have been pooled, which is often done to obtain a better estimate of effect and a narrower confidence interval, and thus a larger M1, the choice may become complicated. In general, if the drugs in a meta-analysis of placebo-controlled trials seem to have similar effects, any of them could be used as an active control. If their observed treatment effects differ, however, even if not significantly, the one with the highest point estimate of effect should ordinarily be used.”11

“Another possibility is a trial in which multiple doses of the investigational drug are compared with the recommended dose or multiple doses of the standard drug. The purpose of this design is simultaneously to show a dose-response relationship for the investigational product and to compare the investigational product with the active control.”3

#### Multiple Outcomes

“The authors should specify for which outcomes noninferiority or equivalence hypotheses apply and for which superiority hypotheses apply.”14

“A clinical trial or clinical programme may plan to show noninferiority for certain variables while superiority may be the objective for others”8

#### Power and Sample Size

“A satisfactory approach to this subject requires an understanding of confidence intervals and the manner in which they capture the results of the trial and indicate the conclusions that can be drawn from them. Such an understanding also leads to an appreciation of why power calculations are of relatively little interest when a trial is complete.”5[italics added]

“A specifically designed noninferiority direct randomised trial would have specified a noninferiority threshold in its power calculation and so might have provided one or more grounds to justify this threshold as a prespecified minimal clinically important difference (MCID).”9

“The acceptable breadth of the CI around the point estimate of the difference between event rates with alternative treatments is one of the principal determinants of sample size”13

“The required sample size is calculated using the confidence interval (CI) approach, considering where the CI for the treatment effect lies with respect to both the margin of noninferiority Δ and a null effect.”14

“The sample size of an equivalence trial or a non-inferiority trial (see Section 3.3.2) should normally be based on the objective of obtaining a confidence interval for the treatment difference that shows that the treatments differ at most by a clinically acceptable difference.”3

“It is important to plan the sample size for an NI clinical trial so that the trial will have the statistical power to conclude that the NI margin is ruled out if the test drug is truly non-inferior.”11

#### Decision Threshold: Definitions

“…the margin of inferiority must be clinically small and not exceed the slightest possible effect of the active control”13

“A margin of clinical equivalence (Δ) is chosen by defining the largest difference that is clinically acceptable, so that a difference bigger than this would matter in practice.”5

“A prestated margin of noninferiority is often chosen as the smallest value that would be a clinically important effect.”14

“… this margin is the largest difference that can be judged as being clinically acceptable and should be smaller than differences observed in superiority trials of the active comparator”.3

“This margin is the degree of inferiority of the test treatments to the control that the trial will attempt to exclude statistically.”4

“It is therefore usual in NI [non-inferiority] studies to choose a smaller margin (M2) that reflects the largest loss of effect that would be clinically acceptable. This can be described as an absolute difference in effect (typical of antibiotic trials) or as a fraction of the risk reduction provided by the control (typical in cardiovascular outcome trials). Note that the clinically acceptable margin could be relaxed if the test drug were shown to have some important advantage (e.g., on safety or on a secondary endpoint).”11

#### Decision Threshold: A Priori Specification

“It is always possible to choose a value of Δ which leads to a conclusion of equivalence or non-inferiority if it is chosen after the data have been inspected. Since the choice of Δ is generally a difficult one, there is ample room for bias here, however well-intentioned the researcher may be. Plausible arguments may often be advanced for a retrospective choice. In the design of equivalence and non-inferiority trials, this reason (amongst others) makes it necessary for the choice of Δ, and the reasoning behind the choice, to be set down in advance by the researcher in the study protocol.”5

“Although there is some variability in the definitions, equivalence trials are based on an active control, aiming to match the action of an established therapy and prove this to statistical significance within a predetermined range (Δ) in both positive and negative directions (a 2-sided test).”13

“The results should be evaluated by using the predefined criteria for defining equivalence or non-inferiority and the rationale for the criteria and support for the determination that the study (studies) had assay sensitivity should be provided (see ICH E10).”7

“Because proof of exact equality is impossible, a prestated margin of noninferiority (Δ) for the treatment effect in a primary patient outcome is defined.”14

The Japan PMDA10 stated that for showing non-inferiority/superiority against an active control, regulators should determine answers to the question “Is the endpoint appropriate and is the pre-determined non-inferiority limit (Δ) appropriate (in the case of a non-inferiority study)?”10

“An equivalence margin should be specified in the protocol”.3

“Prior to the trial, an equivalence or non-inferiority margin, sometimes called Δ, is selected.”4

“In order to demonstrate non-inferiority, the recommended approach is to pre-specify a margin of noninferiority in the protocol”8

“As described above, the NI study seeks to show that the difference in response between the active control (C) and the test drug (T), (C-T), the amount by which the control is superior to test drug, is less than some pre-specified non-inferiority margin (M).”11

#### Decision Threshold: Determining and Justifying

One EMEA document8 focused entirely on this issue; see http://www.ema.europa.eu/docs/en_GB/document_library/Scientific_guideline/2009/09/WC500003636.pdf

It stated “The choice of Δ must always be justified on both clinical and statistical grounds. It always needs to be tailored specifically to the particular clinical context and no rule can be provided that covers all clinical situations. However, certain principles can be used to provide general guidance.”8

Also see the FDA document11 section III.A.4 (starting on page 7) and section IV (starting on page 17) that discuss this issue in detail (http://www.fda.gov/downloads/Drugs/GuidanceComplianceRegulatoryInformation/Guidances/UCM202140.pdf). This document states that the critical threshold for the non-inferiority (NI) study is M2, which is based on first determining M1, which is the “treatment effect of the active comparator”. “The determination of M2 is based on clinical judgment and is usually calculated by taking a percentage or fraction of M1.” “Deciding on the NI clinical margin M2 is also a relatively straightforward concept. It is plainly a matter of judgment about how much of the treatment effect must be shown to be preserved, a consideration that may reflect the seriousness of the outcome, the benefit of the active comparator, and the relative safety profiles of the test and comparator.”11

“A typical value for M2 is often 50% of M1, at least partly because the sample sizes needed to rule out a smaller loss become impractically large.”11

“…explain and justify on clinical or other grounds the value of the noninferiority threshold difference in treatment effect”9

“Demonstrate that a systematic approach has been taken in the search for relevant and appropriate references to support the nominated threshold”9

“Discuss the clinical importance of the primary outcome and secondary outcomes listed in Tables B.5.1 and B.5.2. For primary outcomes, this might be informed by the basis given in the trial protocol for the minimal clinically important difference used in the power calculation. Discuss clinical importance in terms of both relative and absolute changes”9

“The size of the acceptable margin depends on the smallest clinically significant difference (preferably established by independent expert consensus), expected event rates, the established efficacy advantage of the control over placebo, and regulatory requirements.”13

“A prestated margin of noninferiority Δ can be specified as a difference in means or proportions or the logarithm of an odds ratio, risk ratio, or hazard ratio.”14

“When designing an equivalence or noninferiority trial, it may be preferable to express the marginal difference between event rates in terms of constant ratios. When patients at lower risk dilute the target population, event rates should decrease by the same proportion in the groups assigned to each treatment. Even when event rates are variable, it may also be helpful to assess trial results with odds ratios and CI techniques.”13

“For non-inferiority trials used to demonstrate efficacy, the evidence supporting a determination that the trial had assay sensitivity and justifying the choice of non-inferiority margin.”12

“There are several techniques to determine Δ, its magnitude being influenced by several factors, e.g., efficacy, safety, cost, acceptability, and adherence.”14

Piaggio et al. (2006)14 listed one required reporting item (item 7) that authors should specify the margin of equivalence as well as “the rational for its choice”.14

“The margin of noninferiority or equivalence should be specified, and preferably justified on clinical grounds”.14

“The choice of a ‘clinically acceptable’ difference needs justification with respect to its meaning for future patients, and may be smaller than the ‘clinically relevant’ difference referred to above in the context of superiority trials designed to establish that a difference exists.3

“The choice of equivalence margins should be justified clinically”.3

“An acceptable non-inferiority margin should be defined, taking into account the historical data and relevant clinical and statistical considerations”.4

“The determination of the margin in a non-inferiority trial is based on both statistical reasoning and clinical judgment, should reflect uncertainties in the evidence on which the choice is based, and should be suitably conservative.”4

“The margin chosen for a non-inferiority trial cannot be greater than the smallest effect size that the active drug would be reliably expected to have compared with placebo in the setting of the planned trial. If a difference between active control and the new drug favors the control by as much as or more than this margin, the new drug might have no effect at all.”4

“The margin generally is identified based on past experience in placebo-controlled trials of adequate design under conditions similar to those planned for the new trial, but could also be supported by dose response or active control superiority studies. Regardless of the control groups used in those earlier studies, the value of interest in determining the margin is the measure of superiority of the active treatment to its control, not uncontrolled measures such as change from baseline.”4

In the context of bioequivalence only and the use of AUC-ratio [area under the curve) or Cmax ratio as the outcome: “The 90 percent confidence interval for this measure of relative bioavailability should lie within an acceptance interval of 0.80–1.25.”6

“It is not appropriate to define the non-inferiority margin as a proportion of the difference between active comparator and placebo. Such ideas were formulated with the aim of ensuring that the test product was superior to (a putative) placebo; however they may not achieve this purpose. If the reference product has a large advantage over placebo this does not mean that large differences are unimportant, it just means that the reference product is very efficacious”8

“It is not appropriate to use effect size (treatment difference divided by standard deviation) as justification for the choice of non-inferiority margin. This statistic provides information on how difficult a difference would be to detect, but does not help justify the clinical relevance of the difference, and does not ensure that the test product is superior to placebo”8

“Where the treatment under consideration is used for the prevention of death or irreversible morbidity and there is no second chance for treatment it can be very difficult to justify a non-inferiority margin of any size. Discussion of the number of extra deaths that are acceptable is ethically very difficult. However it is not in the best interest of public health to reject all choices of margin. Unless a statistically significant difference has been found between treatments, the confidence interval for the difference will not only indicate that the test product has a possible inferiority to the reference, but it will also show that it has possible superiority. Hence even if we think we are not prepared to accept any possible level of inferiority we are accepting some, by continuing to use the currently authorized product. It is important therefore that non-inferiority trials should still be possible in these areas”5

“Determining the NI margin is the single greatest challenge in the design, conduct, and interpretation of NI trials”11

“As described above, the NI study seeks to show that the difference in response between the active control (C) and the test drug (T), (C-T), the amount by which the control is superior to test drug, is less than some pre-specified non-inferiority margin (M). M can be no larger than the presumed entire effect of the active control in the NI study, and the margin based on that whole active control effect is generally referred to as M1. It is critical to reiterate that M1 is not measured in the NI trial, but must be assumed based on past performance of the active control, the comparison of the current NI study with prior studies, and assessment of the quality of the NI study (see below). The validity of any conclusion from the NI study depends on the choice of M1. If, for example, the NI margin is chosen as 10 (because we are sure the control had an effect of at least that size), and the study does indeed rule out a difference of 10 (seeming to demonstrate “effectiveness” of T), but the true effect of C in this study was actually less than 10, say 5, T would not in fact have been shown to have any effect at all; it will only appear to have had such an effect. The choice of M1, and assurance that this effect was present in the trial (i.e., the presence of assay sensitivity) is thus critical to obtaining a meaningful, correct answer in an NI study.”11

“Although the NI margin used in a trial can be no larger than the entire assumed effect of the active control in the NI study (M1), it is usual and generally desirable to choose a smaller value, called M2, for the NI margin. Showing non-inferiority to M1 would provide assurance that the test drug had an effect greater than zero. However, in many cases that would not be sufficient assurance that the test drug had a clinically meaningful effect. After all, the reason for using the NI design is the perceived value of the active control drug. It would not usually be acceptable to lose most of that active control’s effect in a new drug. It is therefore usual in NI studies to choose a smaller margin (M2) that reflects the largest loss of effect that would be clinically acceptable. This can be described as an absolute difference in effect (typical of antibiotic trials) or as a fraction of the risk reduction provided by the control (typical in cardiovascular outcome trials). Note that the clinically acceptable margin could be relaxed if the test drug were shown to have some important advantage (e.g., on safety or on a secondary endpoint).”11

“As described in section III, the selection of a margin for an NI study is a two-step process. The first step involves making a reasonable assumption about the effect of the active comparator in the NI study. M1 is chosen to equal that treatment effect. If the advantage of the control over the test drug in the NI study is larger than M1, then the test drug has not been shown to have any effect. Effectiveness is therefore demonstrated by showing that the advantage of the control over the test drug (C-T) is smaller than M1. This can be demonstrated by showing that the upper bound of the 95 percent CI of C-T is below M1. This is very similar to testing a superiority finding at P ≤0.05. If we rule out loss of the entire assumed effect of the control, we can conclude that the test drug is superior to placebo. In most situations where active control studies are used, however, assuring some effect greater than zero is not clinically sufficient, and the second step in selecting the NI margin is choosing a specified portion of the control effect (M1) whose loss by the test product must be ruled out. This new non-inferiority margin is called M2, and is based upon clinical judgment. The multiple steps and assumptions that are made in determining an NI margin are all potential sources of uncertainty that may be introduced into the results and conclusions of an NI study. This guidance attempts to identify these sources and suggest approaches to accounting for these uncertainties so that we can reduce the possibility of drawing false conclusions from an NI study.”11

“The choice of margin should be independent of considerations of power. It should be based upon the clinical and statistical principles noted in later sections of this document and not upon issues of sample size, as the size of the clinically important difference is not altered by the size of the study. A small study is not a justification for a wider non-inferiority margin”8

“Let us suppose that a bioequivalence trial finds a 90 percent confidence interval for the relative bioavailability of a new formulation lies that ranges from 0.90 to 1.15. Can we only conclude that the relative bioavailability lies between the conventional limits of 0.80 and 1.25 because these were the pre-defined equivalence margins? Or can we conclude that it lies between 0.90 and 1.15? The narrower interval based on the actual data is the appropriate one to accept…. However, if the trial had resulted in a confidence interval ranging from 0.75 to 1.20, then a post hoc change of equivalence margins to ±25 percent would not be acceptable because of the obvious conclusion that the equivalence margin was chosen to fit the data.”5

### Conducting

“A variety of study quality deficiencies can introduce what is known as a “bias toward the null,” where the observed treatment difference in an NI study is decreased from the true difference between treatments. These deficiencies include imprecise or poorly implemented entry criteria, poor compliance, and use of concomitant treatments whose effects may overlap with the drugs under study, inadequate measurement techniques, or errors in delivering assigned treatments. Many such defects have small (or no) effects on the variability of outcomes (variance) but reduce the observed difference C-T, potentially leading to a false conclusion of non-inferiority. It should also be appreciated that intent-to-treat approaches, which preserve the principle that all patients are analyzed according to the treatment to which they have been randomized even if they do not receive it, although conservative in superiority trials, are not conservative in an NI study, and can contribute to this bias toward the null. It is more important than usual to plan in advance steps to ensure quality during the conduct of an NI study. Finally, it should be recognized that although most investigators seek to carry out high quality trials, the incentives in an NI study are perverse, and quite different from those in superiority trials. In a superiority trial, sloppiness can lead to study failure, and major efforts in trial conduct and monitoring are therefore devoted to avoiding it. In general, sloppiness of any sort obscures true treatment differences. In an NI trial, in contrast, where the goal is to show no difference (or no difference greater than M), poor quality can sometimes lead to an apparent finding of non-inferiority that is incorrect. There is therefore a critical need for particular attention to study quality and conduct when planning and executing an NI study.”11

“To avoid masking differences between treatments, concomitant medications must be carefully addressed. For example, administration of a standard dose of a beneficial concomitant medication to all patients may produce a ceiling effect that masks differences between the treatments under investigation. Use of this medication more often in one treatment group than the other may also bias the result.”13

“A trial to show equivalence or non-inferiority must show a high degree of consistency with protocolled plans if it is to be reliable. Deviations from the inclusion criteria, from the intended treatment regimen, from the schedule, manner and precision of taking measurements, and so on, all tend to reduce the sensitivity of a trial and to make a conclusion of ‘no difference’ more likely, even when the deviations are of an unsystematic or random nature. The size of the bias associated with these and other departures from the protocol is generally unknown and may render such a trial uninterpretable. Failure to show a difference between two treatments can also arise when both treatments are inefficacious, perhaps as a result of being inappropriately administered.”5

“Trial conduct should closely match any trial that demonstrated efficacy of the reference treatment, provided they were of high quality. One should avoid features that might dilute true differences between treatments, thereby enhancing the risk of erroneously concluding noninferiority, e.g., poor adherence, dropouts, recruitment of patients unlikely to respond, and treatment crossovers.”14

“The equivalence (or non-inferiority) trial is not conservative in nature, so that many flaws in the design or conduct of the trial will tend to bias the results towards a conclusion of equivalence. For these reasons, the design features of such trials should receive special attention and their conduct needs special care. For example, it is especially important to minimize the incidence of violations of the entry criteria, non-compliance, withdrawals, losses to follow-up, missing data, and other deviations from the protocol, and also to minimize their impact on the subsequent analyses.”3

“There are many factors in the conduct of a trial that can reduce the observed difference between an effective treatment and a less effective or ineffective treatment and therefore may reduce a trial’s assay sensitivity, such as: 1. Poor compliance with therapy 2. Poor responsiveness of the enrolled study population to drug effects 3. Use of concomitant non-protocol medication or other treatment that interferes with the test drug or that reduces the extent of the potential response 4. An enrolled population that tends to improve spontaneously, leaving no room for further drug-induced improvement 5. Poorly applied diagnostic criteria (patients lacking the disease to be studied) 6. Biased assessment of endpoint because of knowledge that all patients are receiving a potentially active drug, e.g., a tendency to read blood pressure responses as normalized, potentially reducing the difference between test drug and control”4

“…in trials intended to show that there is not a difference of a particular size (noninferiority) between two treatments, there may be a much weaker stimulus to engage in many of these efforts to ensure study quality that will help ensure that differences will be detected, i.e., that ensure assay sensitivity. The kinds of trial error that diminish observed differences between treatments (e.g., poor compliance, high placebo response, certain concomitant treatment, misclassification of outcomes) are of particular concern with respect to preservation of assay sensitivity.”4

“As noted, to determine that a non-inferiority trial had appropriate trial conduct, its conduct should be reviewed not only for the presence of factors that might obscure differences between treatments but also for factors that might make the trial different from the trials that provided the basis for determining the non-inferiority margin. In particular, it should be determined whether any observed differences in the populations enrolled, the use of concomitant therapies, compliance with therapy, and the extent of, and reasons for, dropping out could adversely affect assay sensitivity. Even when the design and conduct of a trial appear to have been quite similar to those of the trials providing the basis for determining the non-inferiority margin, outcomes with the active control treatment that are visibly atypical (e.g., cure rate in an antibiotic trial that is unusually high or low) can indicate that important differences existed.”4

“Other sources of bias that could occur in any study are also of concern in the NI study and are of particular concern in an open label study. For such open label NI studies, how best to ensure unbiased assessment of endpoints, unbiased decisions about inclusion of patients in the analysis, and a wide variety of other potential biases, need particular attention.”11

“Selection of subjects for an active control trial can affect outcome; the population studied should be carefully considered in evaluating what the trial has shown. For example, if many subjects in a trial have previously failed to respond to the control treatment, there would be a bias in favor of the new treatment.”4

One of the reporting items listed by Piaggio et al. (2006)14 was item 3: “Eligibility criteria for participants (detailing whether participants in the noninferiority or equivalence trial are similar to those in any trial[s] that established efficacy of the reference treatment) and the settings and locations where the data were collected.”14

“In examining the results of a comparison of two treatments, it is important to consider whether an apparently less effective treatment has been used at too low a dose or whether the apparently less well tolerated treatment has been used at too high a dose.”4

“Any conclusion of noninferiority should be accompanied by a determination of equi-effective doses”9

“Calculate equi-effective doses at ‘steady state’. In other words, the dose of each drug should be the average dose used by the remaining participants after dose titrations are complete and after excluding participants who discontinue the drug (note that this is similar to the method used to calculate doses from Level 5 evidence). Assess the impact of extrapolating dose titration if there is evidence that the trial was of inadequate duration for the doses to have reached steady state”9

“Dosing should be well founded, because too high or low a dose for either or both treatments could fall below or exceed a critical threshold and lead to an erroneous conclusion of equivalency.”13

### Analyzing

#### Intention-to-treat (ITT)

…“indicate whether the analysis of each trial was conducted on a per protocol basis (which is appropriate for an analysis in support of a conclusion of noninferiority, because it helps examine any impact on the conclusions of losses to follow-up or poor compliance), as well as the standard intention-to-treat (ITT) basis (which is the generally preferred basis for an analysis; see Part II, Subsection B.2).”9

“A combination of efficacy and intention-to-treat analyses is necessary to promote full understanding of data from all randomized patients in this type of trial. The investigators must prespecify which method will be primary. If the 2 approaches give marginally different results, the investigators should trust the least positive result as valid.”13

“In a non-inferiority trial, the full analysis set and the PP [per-protocol] set have equal importance and their use should lead to similar conclusions for a robust interpretation.”5

“In a superiority trial the full analysis set, based on the ITT (intention-to-treat) principle, is the analysis set of choice, with appropriate support provided by the PP (per protocol) analysis set. In a non-inferiority trial the full analysis set and the PP analysis set have equal importance and their use should lead to similar conclusions for a robust interpretation. A switch of objective would require this difference of emphasis to be recognized.”5

“In noninferiority trials, ITT analysis will often increase the risk of falsely claiming noninferiority (type I error), although not always.”14

“Alternative analyses that exclude patients not taking allocated treatment or otherwise not protocol-adherent could bias the trial in either direction. The terms on-treatment or per-protocol analysis are often used but may be inadequately defined. Potentially biased non-ITT analysis is less desirable than ITT in superiority trials but may still provide some insight. In noninferiority and equivalence trials, non-ITT analyses might be desirable as a protection from ITT’s increase of type I error risk (falsely concluding noninferiority). There is greater confidence in results when the conclusions are consistent.”14

“Subjects who withdraw or dropout of the treatment group or the comparator group will tend to have a lack of response, and hence the results of using the full analysis set (see Glossary) may be biased toward demonstrating equivalence.”3

“The full analysis set and the per protocol set play different roles in superiority trials (which seek to show the investigational product to be superior), and in equivalence or non-inferiority trials (which seek to show the investigational product to be comparable, see section 3.3.2). In superiority trials the full analysis set is used in the primary analysis (apart from exceptional circumstances) because it tends to avoid over-optimistic estimates of efficacy resulting from a per protocol analysis, since the non-compliers included in the full analysis set will generally diminish the estimated treatment effect. However, in an equivalence or non-inferiority trial use of the full analysis set is generally not conservative and its role should be considered very carefully.”3

“It should also be appreciated that intent-to-treat approaches, which preserve the principle that all patients are analyzed according to the treatment to which they have been randomized even if they do not receive it, although conservative in superiority trials, are not conservative in an NI study, and can contribute to this bias toward the null.”11

“Intent-to-treat (ITT) analyses in superiority trials are nonetheless preferred because they protect against the kinds of bias that might be associated with early departure from the study. In non-inferiority trials, many kinds of problems fatal to a superiority trial, such as non-adherence, misclassification of the primary endpoint, or measurement problems more generally (i.e., “noise”), or many dropouts who must be assessed as part of the treated group, can bias toward no treatment difference (success) and undermine the validity of the trial, creating apparent non-inferiority where it did not really exist. Although an “as-treated” analysis is therefore often suggested as the primary analysis for NI studies, there are also significant concerns with the possibility of informative censoring in an as-treated analysis. It is therefore important to conduct both ITT and as-treated analyses in NI studies. Differences in results using the two analyses will need close examination.”11

#### Use Confidence intervals

“The appropriate comparison to present is the point estimate of the difference with its 95 percent confidence interval. This allows PBAC to assess whether the confidence interval contains the minimal clinically important difference”9

“The CI provides more information than the P value in both superiority and equivalence, and noninferiority trials, because the CI not only evaluates the null hypothesis but indicates the effect size and the lower and upper bounds of the this estimate, as well”13

About non-inferiority: “Again a confidence interval approach is the most straightforward way of performing the analysis but now we are only interested in a possible difference in one direction.”5

“The interpretation of superiority trials as non-inferiority trials and vice versa is best approached by expressing the results as a confidence interval for the difference between the test treatment and control. There is no fundamental problem associated with the use of this confidence interval as a basis for either mode of interpretation.”5

“If the objective of an active control trial was to show equivalence or non-inferiority, the difference or the ratio of outcomes between treatments should be given with the confidence interval.”7

“Although a modified hypothesis testing framework exists, a more informative CI approach is preferred in the design, analysis, and reporting of noninferiority and equivalence trials.”14

“Equivalence is inferred when the entire confidence interval falls within the equivalence margins”.3

In the context of bioequivalence only: “The statistical method for testing bioequivalence is based upon the 90 percent confidence interval for the ratio of the population means (Test/Reference), for the parameters under consideration.”6

“After study completion, a two-sided 95 percent confidence interval (or one-sided 97.5 percent interval) for the true difference between the two agents will be constructed. This interval should lie entirely on the positive side of the non-inferiority margin.”8

“Again, non-inferiority is established by showing that the upper bound of the two-sided confidence interval for C-T is < M1.”11

#### One-tailed/two-tailed

“…equivalence trials are based on an active control, aiming to match the action of an established therapy and prove this to statistical significance within a predetermined range (d), in both positive and negative directions (a 2-sided test)”13

“Noninferiority trials are statistically based on a 1-sided comparison to an active control in the positive direction (a 1-sided test).”13

“For non-inferiority trials a one-sided interval should be used”.3

“…two-sided 95 percent confidence intervals are to be used for all clinical trials whatever their objective. Among other benefits, this preserved consistency between significance testing and subsequent estimation….If one-sided intervals are used, then they should be used with a coverage probability of 97.5 percent. In the special case of bioequivalence studies, two-sided 90 percent confidence intervals have been established as the norm…”5

“Again, non-inferiority is established by showing that the upper bound of the two-sided [95%] confidence interval for C-T is < M1.”11

“Many noninferiority trials based their interpretation on the upper limit of a 1-sided 97.5 percent CI, which is the same as the upper limit of a 2-sided 95 percent CI. Although both 1-sided and 2-sided CIs allow for inferences about noninferiority, we suggest that 2-sided CIs are appropriate in most noninferiority trials. If a 1-sided 5 percent significance level is deemed acceptable for the noninferiority hypothesis test (a decision open to question), a 90 percent 2-sided CI could then be used.”14

#### Adjustment for multiple outcomes

“A possibility that has thus far had relatively little attention is to have different endpoints with different goals (e.g., superiority on the composite endpoint of death, AMI, and stroke, but NI on death alone). The multiple endpoints would require some alpha adjustment in such a case, but the procedures here are not well defined. Similarly, if a study had several doses, with interest in NI on each of them and, at the same time, interest in a potential superiority finding for one or more doses, the analytical approach is not yet fully established, although it is clear that some correction for multiplicity would be needed.”11

“When there are multiple endpoints or multiple doses of the test treatment evaluated in an NI study, the valid statistical decision tree can be very complex. Using the same 95 percent confidence interval to test non-inferiority and superiority at each endpoint level or at each dose may inflate the overall Type I error rate associated with drawing one or more false conclusions from such multiple comparisons, regardless of whether they are non-inferiority or superiority testing. Thus, for any statistical decision tree composed of tests of superiority and non-inferiority in multiple comparison settings, it is imperative to evaluate the overall Type I error rate for all the comparisons involved in the testing and make appropriate statistical adjustments.”11

### Interpreting/reporting

#### Drawing conclusions

“…it is not adequate to demonstrate the absence of a statistically significant difference between the treatments to claim equivalence; such a lack of a significant difference might occur when the trials are too small to demonstrate a real difference in the effects of the interventions.”9

“The difference between lack of proof of superiority and “equivalence” is important. In other words, a lack of “evidence of a difference” is not the same as evidence of a lack of difference.”13

“Concluding equivalence or non-inferiority based on observing a non-significant test result of the null hypothesis that there is no difference between the investigational product and the active comparator is inappropriate”.3

“With 2-sided equivalence the interpretation is analogous, but both margins Δ and −Δ need considering, and claiming equivalence requires the CI to lie wholly between −Δ and Δ.”14

“The presence of assay sensitivity in a non-inferiority or equivalence trial may be deduced from two determinations: 1) Historical evidence of sensitivity to drug effects, i.e., that similarly designed trials in the past regularly distinguished effective treatments from less effective or ineffective treatments and 2) Appropriate trial conduct, i.e., that the conduct of the trial did not undermine its ability to distinguish effective treatments from less effective or ineffective treatments.”4

#### Drawing a superiority conclusion based on data from a non-inferiority trial

“If the 95 percent confidence interval for the treatment effect not only lies entirely above –Δ but also above zero then there is of superiority in terms of statistical significance at the 5 percent level (p<0.05)….In this case it is acceptable to calculate the p-value associated with a test of superiority and to evaluate whether this is sufficiently small to reject convincingly the hypothesis of no difference. There is no multiplicity argument that affects this interpretation because, in statistical terms, it corresponds to a simple closed test proceedure.”5

“Once noninferiority is evident, it is acceptable to then assess whether the new treatment appears superior to the reference treatment, using an appropriate test or CI (ie, not just the point estimate), preferably defined a priori and with an ITT analysis.”14

“In some cases, a study planned as an NI study may show superiority to the active control. ICH E-9 and FDA policy has been that such a superiority finding arising in an NI study can be interpreted without adjustment for multiplicity. Showing superiority to an active control is very persuasive with respect to the effectiveness of the test drug, because demonstrating superiority to an active drug is much more difficult than showing superiority to placebo.”11

“The designer of an NI trial might hope that the test drug is actually superior to the control. It is possible to design the NI study to first test the hypothesis of NI with the pre-specified margin, and then if this test is successful, proceed to analyze the study for a superiority conclusion. This sequential strategy is entirely acceptable. No statistical adjustment is required.”11

“Noninferiority trials [but not equivalence trials] allow for the possibility of superiority over an active control. Before superiority can be assessed, noninferiority must be established; it would not make sense to start by proving equivalence”13

#### Drawing a superiority conclusion based on data from an equivalence trial

“Noninferiority trials [but not equivalence trials] allow for the possibility of superiority over an active control. Before superiority can be assessed, noninferiority must be established; it would not make sense to start by proving equivalence”13

“In most cases a successful NI study supports effectiveness of the test drug, but it only rarely will support a conclusion that the drug is “equivalent” or “similar” to the active control, a concept that has not been well-defined for these situations. Such similarity might be concluded, however, if the point estimate of the test drug favored it over the control and the upper bound of the 95 percent CI for C-T was close to showing superiority. Where the chosen M2 is very small compared to the control drug effect (e.g., a 10% margin in an antibiotic trial in urinary tract infections where response rate is 80%), it might be concluded that the effectiveness of the test drug and control are very similar.”11

#### Drawing a non-inferiority conclusion based on data from a superiority trial

“If a superiority trial fails to detect a significant difference between treatments, there may be interest in the lesser objective of establishing non-inferiority. If the results of the superiority trial are summarized by means of a 95 percent confidence interval for the treatment difference, the lower end of that confidence interval provided a quantitative estimate of the minimum estimated effect of the new treatment relative to the comparator. When the study protocol contains an acceptable, prospectively defined margin –Δ for non-inferiority, downgrading the objective presents less methodological problems…. Although there does not appear to be a statistical multiplicity issue per se related to this switch of objective, that does not diminish the difficulties associated with the post hoc definition of Δ.”5

“It is inappropriate to claim noninferiority post hoc from a superiority trial unless clearly related to a predefined margin of equivalence. That is, both superiority and noninferiority hypotheses need explicit specification in the trial protocol.”14

“Seeking an NI conclusion in the event of a failed superiority test would almost never be acceptable. It would be very difficult to make a persuasive case for an NI margin based on data analyzed with study results in hand. If it is clear that an NI conclusion is a possibility, the study should be designed as an NI study.”11

“A comparator chosen for a demonstration of superiority may not be acceptable for a conclusion of non-inferiority.”5 See further comments on this issue in reference5 as it related to switching the objective from superiority to non-inferiority.

#### Reporting

Gomberg-Maitlin et al. (2003)13 listed 6 items to be reported:

1. “A table comparing the inclusion and exclusion criteria with those of previous trials on which the standard therapy was based.”
2. “A flow diagram delineating the number of eligible patients screened, the number randomized, the number of patients assigned to each group, the number of withdrawals and crossovers, and the number of patients in each group who successfully completed the trial on assigned treatment.”
3. “A statement of the projected and actual total treatment exposure (patient-years), the minimum per-patient exposure, and the respective impact of withdrawals and crossovers on exposure to initially assigned treatment.”
4. “The rationale for setting the margin of acceptable difference with specific reference to the minimum clinically important treatment effect and with the established efficacy advantage for the control over placebo. Where event rate ratios or floating margins are utilized, the rationale for their use, their prespecified criteria for adjustment, and the margin or ratios used to determine sample size should be provided.”
5. “The minimum requisite number of primary events should be established at the outset.”
6. “A comparison of event rates during treatment with the active control in the trial and in the historical trials that established its efficacy compared with placebo….Though no external method currently exists to evaluate the pragmatic utility of this approach, the 6 elements listed above (taken together) provide a readily accessible index of trial quality”13

Piaggio et al. (2006)14 listed 22 items to be reported:

1. “How participants were allocated to interventions (eg, “random allocation,” “randomized,”or “randomly assigned”), specifying that the trial is a noninferiority or equivalence trial.”
2. “Scientific background and explanation of rationale, including the rationale for using a noninferiority or equivalence design.”
3. “Eligibility criteria for participants (detailing whether participants in the noninferiority or equivalence trial are similar to those in any trial[s] that established efficacy of the reference treatment) and the settings and locations where the data were collected.”
4. “Precise details of the interventions intended for each group, detailing whether the reference treatment in the noninferiority or equivalence trial is identical (or very similar) to that in any trial(s) that established efficacy, and how and when they were actually administered.”
5. “Specific objectives and hypotheses, including the hypothesis concerning noninferiority or equivalence.”
6. “Clearly defined primary and secondary outcome measures, detailing whether the outcomes in the noninferiority or equivalence trial are identical (or very similar) to those in any trial(s) that established efficacy of the reference treatment and, when applicable, any methods used to enhance the quality of measurements (eg, multiple observations, training of assessors).”
7. “How sample size was determined, detailing whether it was calculated using a noninferiority or equivalence criterion and specifying the margin of equivalence with the rationale for its choice. When applicable, explanation of any interim analyses and stopping rules (and whether related to a noninferiority or equivalence hypothesis).”
8. “Method used to generate the random allocation sequence, including details of any restriction (eg, blocking, stratification).”
9. “Method used to implement the random allocation sequence (eg, numbered containers or central telephone), clarifying whether the sequence was concealed until interventions were assigned.”
10. “Who generated the allocation sequence, who enrolled participants, and who assigned participants to their groups.”
11. “Whether or not participants, those administering the interventions, and those assessing the outcomes were blinded to group assignment. When relevant, how the success of blinding was evaluated.”
12. “Statistical methods used to compare groups for primary outcome(s), specifying whethera 1- or 2-sided confidence interval approach was used. Methods for additional analyses, such as subgroup analyses and adjusted analyses.”
13. “Flow of participants through each stage (a diagram is strongly recommended).Specifically, for each group report the numbers of participants randomly assigned, receiving intended treatment, completing the trial protocol, and analyzed for the primary outcome. Describe protocol deviations from trial as planned, together with reasons.”
14. “Dates defining the periods of recruitment and follow-up.”
15. “Baseline demographic and clinical characteristics of each group. Numbers analyzed”
16. “Number of participants (denominator) in each group included in each analysis and whether “intention-to-treat” and/or alternative analyses were conducted. State the results in absolute numbers when feasible (eg, 10/20, not 50%).”
17. “For each primary and secondary outcome, a summary of results for each group and the estimated effect size and its precision (eg, 95% confidence interval). For the outcome(s) for which noninferiority or equivalence is hypothesized, a figure showing confidence intervals and margins of equivalence may be useful.”
18. “Address multiplicity by reporting any other analyses performed, including subgroup analyses and adjusted analyses, indicating those prespecified and those exploratory.”
19. “All important adverse events or side effects in each intervention group.”
20. “Interpretation of the results, taking into account the noninferiority or equivalence hypothesis and any other trial hypotheses, sources of potential bias or imprecision and the dangers associated with multiplicity of analyses and outcomes.”
21. “Generalizability (external validity) of the trial findings.”
22. “General interpretation of the results in the context of current evidence.”14