# Example MIDs for Specific Clinical Topics

Table 1 Minimal important differences in outcomes in patients with COPD reported in Make B. (2007)1

Name | Domain | MID | Worst to Best
Forced expiratory volume in 1 second | Single domain/measure | 100 ml | NA
Maximal exercise test | Single domain/measure | 10 watts 3–5 watts for severe COPD | NA
Submaximal exercise endurance test | Single domain/measure | 1.75 minutes | NA
Six-minute walk test | Single domain/measure | 37–71 meters 24–28 for severe COPD | NA
Transition Dyspnea index | Functional impairment (FI) Magnitude of task (MT) Magnitude of effort (ME) | 1 unit | −9 to +9
UCSD Shortness of Breath Questionnaire | Severity of shortness of breath during 21 activities of daily living, and three additional questions about fear of harm from overexertion, limitations, and fear caused by shortness of breath | 5–7 units | 120 to 0
Borg scale of perceived dyspnea | Single domain/measure | 2 units | 20 to 6
Visual analog scale of dyspnea | Single domain/measure | 10–20 | 100 to 0
Breathlessness diary | Single domain/measure | 0.2 | 4 to 0
St. George’s Respiratory Questionnaire | Symptoms Activity Impacts | 4 units | 100 to 0
Chronic Respiratory Disease Questionnaire | Dyspnoea Fatigue Emotional functioning Mastery | 0.5 units | 1 to 7
Quality of Well-Being Scale | Mobility Physical activity Social activity 25 symptoms/problem complexes | 0.03 units | 0 to 1
Exacerbations | Single domain/measure | 22% change; 1 exacerbation/year | NA

Table 2 Minimal important differences reported in the Western Ontario McMaster Universities Osteoarthritis Index

Author, Year | Method | Worst to Best Scale | Reference | Definition of Minimally Important Differences
Dougados, 2000^2^ | Anchor | (Varies) WOMAC, Lequesne Functional Severity Index, Global VAS | OARSI Responder Criteria—Proposition A: This emphasizes the domain ‘pain’. A ‘high’ improvement in pain was sufficient to define a responder. However, using this set of criteria, a patient can be also considered as a responder if an improvement of ‘moderate’ magnitude is observed in two of the three domains, i.e., pain, function and patient’s global assessment. OARSI Responder Criteria—Proposition B: This scenario applies equal importance to ‘pain’ and ‘function’, requiring a ‘high’ response of one OR the other. Alternatively, a ‘moderate’ magnitude of response could be present in two of the three domains.. | If there was a ‘high’ improvement in pain: improvement of at least 40% was required (ranging from 40% to 60%) together with an absolute improvement of at least 20 normalized units ranging from 20 to 30. If there was moderate improvement in pain, function, and patient’s global assessment: a relative improvement ranging from 15 to 35% and an absolute improvement from 10 to 20 normalized units.
Angst, 2001^3^ | Anchor | 10 to 0 (for each of the 24 items) WOMAC pain scale | The transition questionnaire was used to gather data from the patients about their current subjective health status in relation to the OA joint in terms of their general health. At the 3-month follow up, patients had to compare their general health status with that of 3 months earlier, i.e., with that at baseline examination, using the assessment categories “much worse,” “slightly worse,” “equal,” “slightly better,” and “much better.” | The mean score difference between the “equal” group and the “slightly better” group = 0.67 was the MID for improvement
Tubach, 2005^4^ | Anchor | 100-0 WOMAC: function scale | At the final visit, patients assessed their response to NSAID treatment on a five point Likert scale (none = no good at all, ineffective drug; poor = some effect but unsatisfactory; fair = reasonable effect but could be better; good = satisfactory effect with occasional episodes of pain or stiffness; excellent = ideal response, virtually pain free).The MCII was determined in patients whose assessment of response to treatment was measured on a five point Likert scale and who had completed the final visit. The MCII was estimated for both the absolute (final value-baseline value) and the relative ((final value-baseline value)/baseline value) changes in each patient reported outcome. It was estimated by constructing a curve of cumulative percentages of patients as a function of the change in score (for example, difference in pain score) among patients whose final evaluation of response to treatment was “good, satisfactory effect with occasional episodes of pain or stiffness”. | Patients with knee OA considered themselves clinically improved if the decrease in function score exceeded 9.1 on the WOMAC function scale
Tubach, 2005^5^ | Anchor | 100-0 WOMAC: function subscale | (1) “What is the level of pain above which you experience difficulties?” (This could be considered close to the external anchor for the PASS.) (2) “What is the level of pain above which you would consider taking a pain killer drug?” (This could be considered close to the external anchor for the LDAS.) | The MID in the high tertile of score is −20 (absolute change)
Weigl, 2006^6^ | Anchor | Varies WOMAC; Transition scale (that investigates the current state of health of the OA joint at the 6 months follow-up compared to its state 6 months earlier(baseline examination) | The transition scale investigates the current state of health of the OA joint at the 6-month follow-up compared to its state 6 months earlier (at baseline examination). | Three different definitions of responder: (1) For the WOMAC global score, a percentage change (100*(change of score/baseline score)) greater or equal to 18% represents an MID in improvement; (2) patients who reported a slightly or a much better health status on the transition scale were classified as responders; (3) responders had to show an MID in improvement on the WOMAC global score and report a health improvement on the transition scale
Stratford, 2007^7^ | Distribution | 4-0 for each of the 5 items WOMAC LK 3.1 | The five pain items of WOMAC that were analyzed were: (1) walking on flat ground; (2) going up or down stairs; (3) at night while in bed; (4) sitting or lying; and (5) standing upright. | 90% of stable patients will display random fluctuations equal to or less than 3.94 when assessed on multiple occasions
Bieleman, 2009^8^ | Anchor | 68-0 WOMAC (Dutch versions)function scale | Functional Capacity Evaluation (FCE) | The cut-off point for the WOMAC scale the cut-off point was ≥21 where subjects had work limitations that corresponded to the physical work limitations on the FCE scale
White, 2010^9^ | Anchor | WOMAC: physical function | The definitions of [MID] were that they were anchored to patient-based indicators of improvement and defined meaningful improvement relative to baseline WOMAC physical function scores. The definitions of [MID] 26% and [MID] Tertile were estimated in a group of people with knee pain reporting a “good, satisfactory effect with occasional episodes of pain or stiffness” following a 4-week course of nonsteroidal antiinflammatory drug (NSAID). The [MID] 17% definition was from a group of people with knee OA who underwent 3 to 4 weeks of inpatient rehabilitation. | 3 definitions of [MID] for WOMAC physical function: [MID] 26% and [MID] 17% defines meaningful improvement as a 26% and 17% decrease in WOMAC physical function (final value minus baseline value/baseline value), respectively, with a minimum absolute decrease of 2 out of 68.
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: pain subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC pain score of 37.58(19.71) was equivalent to patient reporting “A great deal better.”
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: function subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC function score of 34.58 (19.33) was equivalent to patient reporting “A great deal better.”
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: stiffness subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC stiffness score of 34.74(28.38) was equivalent to patient reporting “A great deal better.”
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: pain subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC pain score of 33.87(18.13) was equivalent to patient reporting “somewhat better.” This was considered the MID.
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: function subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC function score of 19.01(17.48) was equivalent to patient reporting “somewhat better.” This was considered the MID.
Escobar, 2007^10^ | Anchor | 100 to 0 WOMAC: stiffness subscale | Patients had to answer a question about improvement in their knee at 6 months and 2 years after intervention. The possible responses were “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” and “a great deal worse.” | At 6 months: Mean change in WOMAC stiffness score of 14.53(26.50) was equivalent to patient reporting “somewhat better.” This was considered the MID.
Quintana, 2006^11^ | Distribution | 100 to 0 WOMAC: pain subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The [MID] for pain subscale of WOMAC was at 22.85.
Quintana, 2006^11^ | Distribution | 100 to 0 WOMAC: functional limitation subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The [MID] for functional limitation subscale of WOMAC was at 12.72.
Quintana, 2006^11^ | Distribution | 100 to 0 WOMAC: stiffness subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The [MID] for stiffness subscale of WOMAC was at 29.14.
Quintana, 2006^11^ | Anchor | 100 to 0 WOMAC: pain subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The MID for pain subscale of WOMAC was at 22.60.
Quintana, 2006^11^ | Anchor | 100 to 0 WOMAC: functional limitation subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The MID for functional limitation subscale of WOMAC was at 17.67.
Quintana, 2006^11^ | Anchor | 100 to 0 WOMAC: stiffness subscale | Six months after the intervention, patients were sent another letter with the questionnaires and additional questions on the clinical aspects of their disease and satisfaction with the intervention. The satisfaction question was dichotomized as being satisfied or not. At this time, patients answered a transitional question about their joint improvement after the intervention. The possible responses included “a great deal better,” “somewhat better,” “equal,” “somewhat worse,” or “a great deal worse.” | The MID for stiffness subscale of WOMAC was at 12.94.
Ornetti, 2011^12^ | PASS based on Anchor | 100 to 0 WOMAC: function subscale | All patients had to assess their current global state (global PASS) by answering ‘Yes’ or ‘No’ in answer to the question “Taking into account all the activities you have during your daily life, your level of pain, and also your functional impairment, do you consider that your current state is satisfactory?” | Patients considered their global state as satisfactory if the WOMAC function was <28.06 (95% CI, 25.74 to 30.38.Global PASS is defined as the value of measurement beyond which patients consider their global state as satisfactory).
Ornetti, 2011^12^ | PASS based on Anchor | 100 to 0 WOMAC: function subscale | PASS for functional state: The PASS of each function scale was defined as the 75th centile of the absolute score among patients who considered their final state as satisfactory. | Patients considered their functional state as satisfactory if the WOMAC function was <28.40 (95% CI, 26.03 to 30.78). Function PASS is defined as the value of measurement beyond which patients consider their functional state as satisfactory.
Ornetti, 2011^12^ | Anchor | 100 to 0 WOMAC: function subscale | All patients had to assess their degree of improvement of global state, on a three-point Likert scale (worsened function, no change, improved function). Among patients who improved, the degree of improvement was scored on a four-point Likert scale (poor, fair, good, excellent). | Patients considered their global state as improved for a change of WOMAC function scale >-17.13 (95% CI, −20.07 to −14.19).Global [MID] is defined as the smallest change in global state that signifies an important improvement in a patient’s symptoms.
Ornetti, 2011^12^ | Anchor | 100 to 0 WOMAC: function subscale | [MID] for functional state: The [MID] of each function scale was defined as the 75th centile of the absolute change in score among patients whose final evaluation of response to NSAID was improved (improvement good or excellent). | Patients considered their functional state as improved for a change of WOMAC function scale >-17.02 (95% CI, −20.15 to −13.90). Functional [MID] is defined as the smallest change in functional state that signifies an important improvement in a patient’s symptoms.

Table 3 Clinically important differences in group outcomes in bone density studies reported in Cranney, et al. (2001)13

Classification | Method | Spine | Femoral Neck
Minimum actually detectable beyond error in differences between groups and changes within group14 | Calculated SD of short-term and long-term intra- and inter-subject variance for rates of change in g/cm^2^/year as minimal detectable beyond error in group | Sample size decreased as length of follow-up and frequency of observations increased | NA
Differences between groups and changes within group observed in those estimated to differ/to have improved15,16 | Effect size = mean in treatment less mean in placebo divided by SD of placebo | Better responsiveness for spine BMD than other sites | NA
Differences between groups and changes within group observed in those estimated to differ/to have improved17 | Different cut-offs of % change in spine BMD used to define a responder in 3 year RCT | Choice of cut-off affects results of RCT | NA
Differences between groups and changes within group observed in those estimated to differ/to have improved18 | Treatment response index = difference in % change between groups of RCT divided by standardized precision in 4 year RCT of hormone replacement therapy (HRT) for early, non-osteoporotic post-menopausal women | Treatment response index: DXA spine 10.4(0.5) DXA total hip 3.9(0.4) BUA 3.1(1.2) SOS 0.3(13.7) Stiffness 4.2(0.4) | NA
Differences between groups and changes within group observed in those estimated to differ/to have improved19 | Compared dose-related % change in BMD in 2 RCTs and differences between treated and placebo groups Correlated changes in new region of interest in forearm to changes in BMD at the spine and hip | New region of interest in forearm is as responsive to change over time during therapy in an RCT as spine or hip BMD | New region of interest in forearm is as capable of detecting differences between groups
Differences between groups and changes within group observed in those estimated to have an important difference/improvement20 | Clinician judgment that group difference or change should be greater than SD to be important | 5% | 8%
Changes within group observed in population21 | Used 3 arbitrary cut-offs (0%, 0–3%, >3% change in spine, hip, and femoral neck BMD) | >3% change predicted fewer vertebral fractures: Spine 6%, 4%, 3.7% Femoral neck 5.5%, 4.2%. 3.1% Total Hip 6.2%, 4.6%, 2.7%
Differences between groups observed in those estimated to have an important difference/improvement22 | Working party of 14 European experts in osteoporosis | 15% reduction in fracture frequency suggested as MID, depending on unwanted effects

Table 4 Reduction in bone fractures corresponding to importance of the effect reported in Cranney et al. (2001)13

Classification of Discrimination and Changes in Studies of Osteoporosis | Method | Outcomes
Differences between groups and changes within group observed in those estimated to differ /to have improved15,16 | Effect size = mean in treatment less mean in placebo divided by SD of placebo | Better responsiveness for clinical vertebral in high risk subgroup with femoral neck BMD >2.5 SD
Differences between groups observed in population23 | Tested if different criteria for diagnosis of vertebral fracture would change results of RCT of fluoride | Found no difference between difference between groups for any of the fracture definition criteria
Differences between groups observed in those estimated to have an important difference/ improvement24 | Sample size calculation to detect difference in fractures associated with 1 SD decrease in bone mass | 30% reduction in incidence of vertebral and non-vertebral fractures associated with low bone mass
Differences between groups observed in those estimated to have an important difference/ improvement25 | Evaluated 7 methods of classifying/diagnosing vertebral fracture and calculated sample size for RCT | 40% risk reduction in vertebral fracture
Differences between groups observed in those estimated to have an important difference/ improvement26 | Sample size determination for FIT trial | 40% risk reduction in vertebral fracture 90% power to detect 32% reduction
Differences between groups observed in those estimated to have an important difference/ improvement27 | Sample size calculations for different definitions of vertebral fracture, from 5–30% reduction in height | 50% risk reduction in vertebral fracture
Differences between groups observed in those estimated to have an important difference/ improvement27 | Sample size calculation for 90% power, 2 tailed test, p <0.05 MORE RCT of 7705 post-menopausal women with ≥1 vertebral fracture | 40% risk reduction in vertebral fractures
Differences between groups observed in those estimated to have an important difference/ improvement28 | Sample size calculation for risedronate RCT of 2,458 post-menopausal women with ≥1 vertebral fracture | 40% risk reduction in vertebral fractures
Differences between groups observed in those estimated to have an important difference/ improvement26 | Sample size calculation for RCT of HRT, vitamin D/calcium in post-menopausal women | 21% hip fracture reduction 20% reduction in combined fractures (vertebra, proximal femur, distal forearm, proximal humerus, pelvis)
Differences between groups observed in those estimated to have an important difference/ improvement22 | Working party of 14 European experts in osteoporosis | 15% reduction in fracture frequency suggested as MCID depending on unwanted effects
Differences between groups observed in those estimated to have an important difference/ improvement29 | Cost per averted hip fracture used to determine important difference needed for policy to change | 10% difference in hip fracture incidence with thiazides is cost-neutral

## References

1 Make B. How can we assess outcomes of clinical trials: the MCID approach?. COPD. Sep. 2007;4(3):191-4. [pmid: 17729062].
2 Dougados M, Leclaire P, van der Heijde D, et al. Response criteria for clinical trials on osteoarthritis of the knee and hip: a report of the Osteoarthritis Research Society International Standing Committee for Clinical Trials response criteria initiative. Osteoarthritis Cartilage. Nov. 2000;8(6):395-403. [pmid: 11069723].
3 Angst F, Aeschlimann A, Stucki G. Smallest detectable and minimal clinically important differences of rehabilitation intervention with their implications for required sample sizes using WOMAC and SF-36 quality of life measurement instruments in patients with osteoarthritis of the low. Arthritis Rheum. Aug. 2001;45(4):384-91. [pmid: 11501727].
4 Tubach F, Ravaud P, Baron G, et al. Evaluation of clinically relevant changes in patient reported outcomes in knee and hip osteoarthritis: the minimal clinically important improvement. Ann Rheum Dis. Jan. 2005;64(1):29-33. [pmid: 15208174].
5 Tubach F, Wells GA, Ravaud P, et al. Minimal clinically important difference, low disease activity state, and patient acceptable symptom state: methodological issues. J Rheumatol. Oct. 2005;32(10):2025-9. [pmid: 16206363].
6 Weigl M, Angst F, Aeschlimann A, et al. Predictors for response to rehabilitation in patients with hip or knee osteoarthritis: a comparison of logistic regression models with three different definitions of responder. Osteoarthritis Cartilage. Jul. 2006;14(7):641-51. [pmid: 16513373].
7 Stratford PW, Kennedy DM, Woodhouse LJ, et al. Measurement properties of the WOMAC LK 3.1 pain scale. Osteoarthritis Cartilage. Mar. 2007;15(3):266-72. [pmid: 17046290].
8 Bieleman HJ, Reneman MF, van Ittersum MW, et al. Self-reported functional status as predictor of observed functional capacity in subjects with early osteoarthritis of the hip and knee: a diagnostic study in the CHECK cohort. J Occup Rehabil. Dec. 2009;19(4):345-53. [pmid: 19557505].
9 White DK, Keysor JJ, Lavalley MP, et al. Clinically important improvement in function is common in people with or at high risk of knee OA: the MOST study. J Rheumatol. Jun. 2010;37(6):1244-51. [pmid: 20395640].
10 Escobar A, Quintana JM, Bilbao A, et al. Responsiveness and clinically important differences for the WOMAC and SF-36 after total knee replacement. Osteoarthritis Cartilage. Mar. 2007;15(3):273-80. [pmid: 17052924].
11 Quintana JM, Escobar A, Arostegui I, et al. Health-related quality of life and appropriateness of knee or hip joint replacement. Arch Intern Med. Jan. 23. 2006;166(2):220-6. [pmid: 16432092].
12 Ornetti P, Dougados M, Paternotte S, et al. Validation of a numerical rating scale to assess functional impairment in hip and knee osteoarthritis: comparison with the WOMAC function scale. Ann Rheum Dis. May. 2011;70(5):740-6. [pmid: 21149497].
13 Cranney A, Welch V, Wells G, et al. Discrimination of changes in osteoporosis outcomes. J Rheumatol. Feb. 2001;28(2):413-21. [pmid: 11246689].
14 Nguyen TV, Sambrook PN, Eisman JA. Sources of variability in bone mineral density measurements: implications for study design and analysis of bone loss. J Bone Miner Res. Jan. 1997;12(1):124-35. [pmid: 9240735].
15 Wells G, Cranney A, Shea B, et al. Responsiveness of endpoints in osteoporosis clinical trials. J Rheumatol. Jun. 1997;24(6):1230-3. [pmid: 9195542].
16 Cranney A, Welch V, Tugwell P, et al. Responsiveness of endpoints in osteoporosis clinical trials—an update. J Rheumatol. Jan. 1999;26(1):222-8. [pmid: 9918268].
17 Oppenheimer L, Kher U. The impact of measurement error on the comparison of two treatments using a responder analysis. Stat Med. Aug. 30. 1999;18(16):2177-88. [pmid: 10441772].
18 Sahota O, San P, Cawte SA, et al. A comparison of the longitudinal changes in quantitative ultrasound with dual-energy X-ray absorptiometry: the four-year effects of hormone replacement therapy. Osteoporos Int. 2000;11(1):52-8. [pmid: 10663359].
19 Ravn P, Hosking D, Thompson D, et al. Monitoring of alendronate treatment and prediction of effect on bone mass by biochemical markers in the early postmenopausal intervention cohort study. J Clin Endocrinol Metab. Jul. 1999;84(7):2363-8. [pmid: 10404804].
20 Eastell R. Treatment of postmenopausal osteoporosis. N Engl J Med. Mar. 12. 1998;338(11):736-46. [pmid: 9494151].
21 Hochberg MC, Ross PD, Black D, et al. Larger increases in bone mineral density during alendronate therapy are associated with a lower risk of new vertebral fractures in women with postmenopausal osteoporosis. Fracture Intervention Trial Research Group. Arthritis Rheum. Jun. 1999;42(6):1246-54. [pmid: 10366118].
22 Kanis JA, Geusens P, Christiansen C. Guidelines for clinical trials in osteoporosis. A position paper of the European Foundation for Osteoporosis and Bone Disease. Osteoporos Int. Jun. 1991;1(3):182-8. [pmid: 1790407].
23 Melton LJ 3d, Egan KS, O’Fallon WM, et al. Influence of fracture criteria on the outcome of a randomized trial of therapy. Osteoporos Int. 1998;8(2):184-91. [pmid: 9666944].
24 Seeley DG, Browner WS, Nevitt MC, et al. Which fractures are associated with low appendicular bone mass in elderly women? The Study of Osteoporotic Fractures Research Group. Ann Intern Med. Dec. 1. 1991;115(11):837-42. [pmid: 1952469].
25 Black DM, Palermo L, Nevitt MC, et al. Defining incident vertebral deformity: a prospective comparison of several approaches. The Study of Osteoporotic Fractures Research Group. J Bone Miner Res. Jan. 1999;14(1):90-101. [pmid: 9893070].
26 Black DM, Reiss TF, Nevitt MC, et al. Design of the fracture intervention trial. Osteoporos Int. 1993;3(Suppl 3):S29-39. [pmid: 8298200].
27 Kleerekoper M, Nelson DA, Peterson EL, et al. Outcome variables in osteoporosis trials. Bone. 1992;13(Suppl 1):S29-34. [pmid: 1581116].
28 Harris ST, Watts NB, Genant HK, et al. Effects of risedronate treatment on vertebral and nonvertebral fractures in women with postmenopausal osteoporosis: a randomized controlled trial. Vertebral Efficacy With Risedronate Therapy (VERT) Study Group. JAMA. Oct. 13. 1999;282(14):1344-52. [pmid: 10527181].
29 Torgerson DJ, Ryan M, Ratcliffe J. Economics in sample size determination for clinical trials. QJM. Jul. 1995;88(7):517-21. [pmid: 7633878].