# Results

## Data Description

The years of publication of the included papers are shown in Figure 5.

Figure 5 Year of publication of included studies

EPC = Evidence-based Practice Center

Figure 5 is a line graph showing the year of publication of included studies for the three datasets. The chart starts with the year 1960 and ends with the year 2006, Y-axis has percentage values ranging from 0 to 15. The figure is further explained in the text as follows: The three datasets showed some differences: dataset 3 (published ‘pro-bias’ dataset) included many older papers with a peak in the 1990s compared to the other datasets and all studies were published before 1996. The dataset 1 (back pain data) included mainly newer publications, several published in the last decade. The studies included in the EPC reports were published over a large period of time, with no particular peak.

The three datasets showed some differences: dataset 3 (published “pro-bias” dataset) included many older papers with a peak in the 1990s compared to the other datasets and all studies were published before 1996. The dataset 1 (back pain data) included mainly newer publications, several published in the last decade. The studies included in the Evidence-based Practice Center (EPC) reports were published over a large period of time, with no particular peak.

### Relationship Between Total Quality Scores and Year of Publication

We investigated in each dataset the relationship between a quality sum score based on the mean of the assessed quality features and the year of publication. Figure 6 plots both variables.

Figure 6 Total quality and year of publication

Note: data points have been “jittered” to avoid overlap.

Figure 6 shows three scatter plots, plotting the quality and year of publication for each of the three datasets.

In addition, the difference in quality between pre- and post-Consolidated Standards of Reporting Trials (CONSORT) publications was tested (1996 used as cutoff). In the back pain dataset, the difference in total scores between pre- and post-CONSORT published trials was 0.58 (SE 0.32, p=0.07) on the 11-item scale. The quality of studies published after the introduction of the CONSORT statement was better but not statistically significantly higher. In the EPC report dataset the difference between pre- and post-CONSORT quality ratings was 1.35 (SE 0.32, p<0.001). All studies included in the third dataset were published before the introduction of CONSORT.

To ensure that the effect was not an artifact of the fact that quality of studies was improving over time anyway, regardless of CONSORT, we estimated the effect of time for papers published both pre- and post-CONSORT. These effects were not statistically significant.

### Quality of the Reporting

Figure 7 shows the distribution of answers to the quality items (yes, unclear, no). A “yes” is an indicator of high quality for all items (randomization sequence, allocation concealment, baseline similarity, outcome assessor blinding, care provider blinding, patient blinding, dropout rate and description, analysis in original group, intention to treat [ITT], cointerventions, compliance, and assessment timing), for example, the outcome assessors were blind.

Figure 7 Quality item answer distribution

Figure 7 shows three bar charts depicting the ‘yes’, ‘no’ and ‘maybe’ answers given to the 11 quality criteria in the three datasets. The figure is further described in the text indicating that in the back pain dataset the presence or absence of quality features is relatively evenly distributed, but the studies included in the EPC reports showed less variation across items, many quality features were either present or there was not enough information to judge the individual quality feature, the answer “no” was very rare. The “unclear” answer was very common in dataset number 2 (EPC reports) and 3 (published ‘pro-bias’ dataset).

In the back pain dataset, the presence or absence of quality features is relatively evenly distributed for most items. Patient and provider blinding was not very common in the included trials and presumably often impossible due to the nature of the interventions. Similar timing of outcome measure assessment in the treatment and the control group was common, but there were a few deviations. The studies included in the EPC reports showed less variation across items. Many quality features were either present or there was not enough information to judge the individual quality feature. The answer “no” was very rare. The “unclear” answer was very common in dataset 2 (EPC reports) and 3 (published “pro-bias” dataset) indicating that the original studies did not report enough information to judge the quality feature. Very few trials scored negatively for the assessed quality features, that is, the reviewer had enough information to know that the design feature was not adhered to (e.g., the patient was not blinded). In datasets 2 and 3 there was virtually no variance in the item “Was the timing of the outcome assessment similar in all groups?” across studies, indicating that this quality feature may be unique to back pain trials.

Figure 8 allows a comparison of “yes” answers across the three datasets.

Figure 8 Criterion met across datasets

EPC = Evidence-based Practice Center

Figure 8 is a bar chart depicting the number of quality criteria met in each dataset for each of the 11 items and shows that the level of criteria met was highest in the EPC report dataset and the lowest quality level across quality criteria was generally observed in the third dataset.

The level of criteria met was highest in the EPC report dataset for the blinding items, similarities of cointerventions, similar timing, and the analysis in the original group assignment (ITT analysis). The lowest quality level across quality criteria was generally observed in the third dataset, which contains older studies, all published before the CONSORT statement.

### Intercorrelations Quality Features

Although conceptually presumably independent, in practice studies that pay attention to one quality feature (e.g., allocation concealment) often do so also for others (e.g., using an adequate method of generating a randomization sequence). To trace the empirical interrelatedness of the quality items, Tables 3–5 show the inter-item correlations of quality features in each of the three datasets.

Table 3 Dataset 2 Inter-item correlations dataset 1 (back pain)

Randomization Adequate | 1.00
Allocation Concealment | 0.53 | 1.00
Similar Baseline | 0.19 | 0.24 | 1.00
Assessor Blind | 0.01 | 0.09 | 0.00 | 1.00
Care Provider Blind | -0.30 | -0.21 | -0.08 | 0.46 | 1.00
Patient Blind | -0.20 | -0.17 | -0.08 | 0.55 | 0.68 | 1.00
Acceptable Dropout Rate | 0.10 | 0.07 | 0.15 | 0.05 | 0.08 | -0.10 | 1.00
Original Group (ITT) | 0.23 | 0.27 | 0.12 | -0.02 | -0.05 | -0.11 | 0.40 | 1.00
Similar Cointerventions | 0.20 | 0.19 | 0.13 | 0.14 | -0.01 | -0.04 | 0.14 | 0.13 | 1.00
Acceptable Compliance | 0.28 | 0.31 | 0.25 | -0.03 | -0.18 | -0.14 | 0.07 | 0.20 | 0.31 | 1.00
Similar Timing | -0.04 | 0.10 | 0.15 | -0.06 | 0.03 | -0.01 | 0.13 | 0.13 | 0.12 | 0.12
| Rand Adequate | Concealed | Similar Baseline | Assessor Blind | Provider Blind | Patient Blind | Dropout Acceptable | Original Group | Co-Intervention | Compliance Accept

ITT = intention to treat

Table 4 Dataset 2 Inter-item correlations dataset 2 (EPC reports)

Randomization Adequate | 1.00
Allocation Concealment | 0.74 | 1.00
Similar Baseline | 0.03 | 0.03 | 1.00
Assessor Blind | 0.01 | 0.06 | -0.07 | 1.00
Care Provider Blind | 0.13 | 0.15 | -0.17 | 0.36 | 1.00
Patient Blind | 0.05 | 0.11 | -0.15 | 0.15 | 0.78 | 1.00
Acceptable Dropout Rate | 0.12 | 0.08 | -0.08 | -0.02 | 0.05 | 0.09 | 1.00
Original Group (ITT) | 0.15 | 0.23 | -0.04 | -0.01 | 0.41 | 0.36 | 0.00 | 1.00
Similar Cointerventions | 0.09 | 0.02 | 0.09 | -0.01 | 0.17 | 0.20 | -0.07 | 0.13 | 1.00
Acceptable Compliance | 0.06 | 0.06 | 0.00 | -0.01 | 0.08 | 0.09 | 0.19 | 0.07 | 0.08 | 1.00
Similar Timing | 0.01 | -0.01 | 0.12 | 0.15 | 0.17 | 0.20 | 0.03 | 0.03 | 0.38 | 0.15
| Rand Adequate | Concealed | Similar Baseline | Assessor Blind | Provider Blind | Patient Blind | Dropout Acceptable | Original Group | Co-Intervention | Compliance Accept

ITT = intention to treat

Table 5 Dataset 3 Inter-item correlations dataset 3 (“pro-bias”)

Randomization Adequate | 1.00
Allocation Concealment | 0.49 | 1.00
Similar Baseline | 0.34 | 0.13 | 1.00
Assessor Blind | 0.02 | 0.15 | 0.25 | 1.00
Care Provider Blind | 0.07 | 0.00 | 0.28 | 0.69 | 1.00
Patient Blind | -0.02 | -0.04 | 0.24 | 0.53 | 0.79 | 1.00
Acceptable Dropout Rate | 0.13 | 0.04 | 0.16 | -0.12 | -0.03 | -0.08 | 1.00
Original Group (ITT) | 0.01 | -0.03 | 0.16 | -0.14 | -0.05 | -0.04 | 0.00 | 1.00
Similar Cointerventions | 0.09 | -0.08 | 0.34 | 0.10 | 0.19 | 0.15 | -0.01 | 0.06 | 1.00
Acceptable Compliance | -0.03 | 0.00 | -0.07 | -0.14 | -0.12 | -0.14 | 0.06 | 0.03 | 0.07 | 1.00
Similar Timing | 0.05 | 0.06 | 0.26 | 0.12 | 0.32 | 0.42 | 0.05 | 0.01 | 0.17 | 0.07
| Rand Adequate | Concealed | Similar Baseline | Assessor Blind | Provider Blind | Patient Blind | Dropout Acceptable | Original Group | Co-Intervention | Compliance Accept

ITT = intention to treat

The mean inter-item correlation in this dataset was 0.1. Some of the items were substantially inter-correlated, for example, was the treatment allocation concealed correlated highly with an adequate randomization sequence, and if studies reported patient blinding, the studies tended to also report provider and outcome assessor blinding. The majority of features showed coherence but did not indicate that items were redundant and the information for one item was contained in another. There were a few negative correlations; the only noteworthy correlation was that the studies that reported an adequate randomization procedure stated that the care providers were not blinded (often impossible in this dataset given the interventions).

The mean inter-item correlation in the EPC reports was r = 0.11. Adequate sequence of randomization and concealment of treatment allocation were highly intercorrelated, as were provider and patient blinding.

The mean inter-item correlation in the third dataset was 0.11, and the pattern was very similar to the two other datasets.

In addition to the newly proposed quality features, we also applied the Jadad scale and the quality features suggested by Schulz et al. (1995) including allocation concealment. Table 6 shows the intercorrelations between the newly proposed items and the features scored according to the Jadad scale instructions and Schulz's original instructions. Correlations in bold indicate corresponding quality domains. As expected, there were strong correlations between Cochrane Back Review Group (CBRG) Internal Validity items and corresponding items for Jadad and Schulz—items describing randomization, concealment, blinding, and dropouts.

Table 6 Correlation of criteria with Jadad and measures proposed by Schulz

Quality Feature | Jadad Randomization | Jadad Blinding | Jadad Withdrawals | Jadad Total | Schulz Concealment | Schulz Sequence | Schulz Analysis | Schulz Blinding
Was the method of randomization adequate? | 0.86 | 0.13 | 0.04 | 0.50 | 0.39 | 0.91 | 0.00 | 0.07
Was the treatment allocation concealed? | 0.44 | 0.12 | -0.01 | 0.29 | 0.84 | 0.46 | 0.06 | 0.04
Were the groups similar at baseline regarding the most important prognostic indicators? | 0.31 | 0.33 | 0.16 | 0.43 | 0.08 | 0.28 | 0.05 | 0.32
Was the outcome assessor blinded? | 0.13 | 0.65 | -0.09 | 0.47 | 0.09 | 0.03 | -0.20 | 0.74
Was the care provider blinded? | 0.13 | 0.82 | 0.05 | 0.64 | -0.05 | 0.06 | 0.03 | 0.93
Were patients blinded? | -0.02 | 0.76 | 0.04 | 0.53 | -0.09 | -0.03 | 0.11 | 0.87
Was the dropout rate acceptable? | 0.12 | 0.02 | 0.76 | 0.34 | 0.04 | 0.15 | -0.27 | -0.04
Were all randomized participants analyzed in the group to which they were originally assigned? | -0.03 | -0.12 | 0.13 | -0.05 | 0.02 | -0.03 | 0.63 | -0.05
Were cointerventions avoided or similar? | 0.14 | 0.22 | 0.08 | 0.25 | -0.18 | 0.07 | -0.04 | 0.23
Was the compliance acceptable in all groups? | 0.02 | 0.00 | 0.18 | 0.08 | 0.09 | -0.04 | 0.13 | -0.10
Was the timing of the outcome assessment similar in all groups? | 0.11 | 0.31 | 0.08 | 0.30 | 0.06 | 0.02 | 0.10 | 0.35

Note: in bold are correlations reflecting similar constructs.

The correspondence was not perfect, since although assessing similar quality domains, the scoring rules are not identical across quality scoring systems. For example, the CBRG provides a number of rules for when blinding can be assumed when blinding was not explicitly reported in the study (e.g., when automated data are concerned). Schulz's item “Inclusion in the Analysis of All Randomized Participants” instructs that the item should be answered in the affirmative when the publication reports “or gives the impression” that no exclusions have taken place (“often not explicit”), whereas the corresponding CBRG item requires an explicit statement in the text or explicit data; otherwise the item will be scored “unclear.”

### Internal Consistency

In the back pain dataset, the Cronbach's alpha coefficient of a summary scale was 0.56, in the EPC reports alpha was 0.55, and in the third dataset alpha was 0.61, indicating in all three datasets only moderate internal consistency. The level of consistency does not indicate that all items are measuring the same construct.

To investigate whether the internal consistency was mainly influenced by one or two outlying items, the alpha coefficient was computed excluding each item in turn (alpha if item deleted analysis), depicted in Table 7. This analysis can also show whether there are items that do not add any information that is already captured though other items (in that case, the scale alpha does not drop although the item is removed from the scale).

Table 7 Alpha if item deleted

Quality Feature | Scale α if Item Deleted Back Pain [underlined: α=0.56] | Scale α if Item Deleted EPC Reports [underlined: α=0.55] | Scale α if Item Deleted Published Dataset “Pro-bias” [underlined: α=0.61]
Was the method of randomization adequate? | 0.53 | 0.49 | 0.54
Was the treatment allocation concealed? | 0.50 | 0.49 | 0.56
Were the groups similar at baseline regarding the most important prognostic indicators? | 0.53 | 0.61 | 0.48
Was the outcome assessor blinded? | 0.52 | 0.55 | 0.53
Was the care provider blinded to the intervention? | 0.56 | 0.46 | 0.49
Were patients blinded? | 0.57 | 0.47 | 0.51
Was the dropout rate described and acceptable? | 0.53 | 0.57 | 0.59
Were all randomized participants analyzed in the group to which they were originally assigned? | 0.52 | 0.50 | 0.60
Were cointerventions avoided or similar? | 0.51 | 0.53 | 0.54
Was the compliance acceptable in all groups? | 0.52 | 0.55 | 0.61
Was the timing of the outcome assessment in all groups similar? | 0.55 | 0.54 | 0.52

EPC = Evidence-based Practice Center

The “alpha if item removed” scores indicated in the back pain dataset that one of the blinding items may be unnecessary since its absence does not decrease alpha. All other items did not affect the total score substantially, there was also no indication that one particular item was the “odd one out,” not related to an overall quality score constituted by these 11 quality features. In the EPC projects, removing the items that concern the similarity of the baseline would raise alpha slightly, and the outcome assessor blinding item does not add any information that is not already captured by (presumably) the other blinding items. The removal of the compliance item would not lower the Cronbach's alpha value in the third dataset, indicating that this item does not contribute to increased reliability of a total scale.

### Factor Analysis

To investigate the structure of relationships between quality features we fitted one, two, and three factor models in a multiple indicator multiple cause (MIMIC) model to each dataset. The factors group related items, in terms of intercorrelations as well as in their strength of association with effect sizes. For each dataset, we estimated three models—a single quality factor model, two quality factors, and three quality factors. (Figure 3 shows a two quality factor model). Each model was assessed using a range of fit measures, which indicate the degree of misfit between the model and the data. The χ^2^ test should be nonsignificant in a well-fitting model, the comparative fit index should be over 0.95, and the root mean square error of approximation should be less than 0.05.

In meta-analysis, the studies are weighted by the standard error of the estimate. In fitting a MIMIC model, techniques have not been developed that allow us to estimate weights for studies separately; hence, the relationships between effect size and quality factors should be interpreted in this light.

The fit indices for the datasets are shown in Table 8. In the back pain dataset, the patient blinding item and similar timing had to be removed due to collinearity, in the EPC report set the assessor blinding and similar timing had to be removed, and in the third dataset the assessor blinding item was dropped due to lack of variance. A model assuming three factors gave a good fit to the data in all three datasets.

Table 8 Fit indices

Fit Indices | Dataset 1: Back Pain | | | Dataset 2: EPC Reports | | | Dataset 3: “Pro-bias”
Fit Indices | 1 Factor | 2 Factor | 3 Factor | 1 Factor | 2 Factor | 3 Factor | 1 Factor | 2 Factor | 3 Factor
χ^2^ (df) p | 169 (23) <0.001 | N/C | 19.1 (13) 0.120 | 71 (15) <0.001 | N/C | 11.6 (12) 0.47 | 52 (23) <0.001 | 27 (21) 0.18 | 16.1 (19) 0.72
CFI | 0.59 | | 0.98 | 0.96 | | 1.00 | 0.71 | 0.94 | 1.000
RMSEA | 0.171 | | 0.47 | 0.15 | | 0.000 | 0.11 | 0.053 | 0.000

df = degrees of freedom; N/C = model failed to converge; CFI = comparative fit index; RMSEA = root mean square error of approximation

The factor loadings of the individual quality features on the latent factors are shown in Table 9. The largest loading of each item in each dataset is highlighted in bold. Factor loadings are the correlations of each quality feature with the factor. Factor loadings constitute the factors.

Table 9 Standardized factor loadings

Quality Feature | Back Pain | | | EPC Reports | | | Published Set “Pro-bias”
Quality Feature | F1 | F2 | F3 | F1 | F2 | F3 | F1 | F2 | F3
Randomization adequate | 0.82 | -0.07 | 0.02 | 0.94 | -0.04 | 0.06 | 0.77 | 0.45 | -0.01
Allocation concealment | 0.92 | 0.08 | 0.02 | 0.99 | 0.04 | -0.02 | 1.05 | 0.00 | 0.30
Similar baseline | 0.41 | 0.00 | 0.18 | 0.17 | -0.28 | -0.16 | 0.35 | 1.06 | 0.01
Assessor blind | 0.22 | 1.01 | -0.08 | | | | 0.18 | -0.01 | 0.95
Care provider blind | -0.42 | 0.83 | 0.14 | 0.03 | 0.98 | -0.01 | 0.00 | 0.12 | 0.96
Patient blind | | | | -0.07 | 0.99 | 0.06 | -0.16 | 0.15 | 0.83
Acceptable dropout rate | 0.00 | 0.00 | 0.99 | 0.03 | 0.01 | 0.95 | 0.16 | 0.29 | -0.24
Original group (ITT) | 0.31 | -0.08 | 0.58 | 0.27 | 0.56 | -0.15 | -0.03 | 0.33 | -0.30
Similar cointerventions | 0.43 | 0.20 | 0.17 | 0.11 | 0.32 | -0.18 | -0.07 | 0.61 | -0.05
Acceptable compliance | 0.59 | -0.05 | 0.13 | 0.05 | 0.12 | 0.25 | -0.01 | 0.06 | -0.25
Similar timing | | | | | | | 0.00 | 0.42 | 0.40

Note: loadings in bold are significant (p<0.05).

EPC = Evidence-based Practice Center; F = factor; ITT = intention to treat

Factor one in the back pain dataset consisted mainly of the randomization sequence item, allocation concealment, and the compliance item. Baseline similarity and the similarity of cointerventions also loaded on this item. Factor two represented blinding. Factor three was made up of the acceptable dropout item across datasets and the ITT item (original group) in two out of the three datasets. The correlations between factors were not statistically significant (F1, F2: -0.14 [p=.224]; F1, F3: 0.13 [p=0.281]; F2, F3: 0.11 [p=0.252]).

In the EPC report, dataset factor one consisted of randomization sequence and allocation concealment. Items relating to blinding loaded on factor 2 as did the original group, co-intervention and similar baseline items. The only item with a high loading on factor 3 was the dropout measure. The correlations between factors were not statistically significant (F1, F2: 0.24 [p=.056]; F1, F3: 0.15 [p=.230]; F2, F3: 0.09 [p=.446]).

In the third dataset, the randomization item and allocation concealment loaded again on factor 1. Factor 3 was the blinding factor, but factor 2 consisted mainly of similar baseline and similar co-intervention reporting and a couple of other items also loaded on this factor. The correlations between factors were not statistically significant (F1, F2: -0.22 [p=.553]; F1, F3: -0.20 [p=.392]; F2, F3: -0.42 [p=0.019]).

Similarities across all three datasets were that the randomization and concealment items formed one “treatment allocation” factor. Blinding constituted another robust factor across datasets, independent from the treatment allocation factor. In each dataset a third factor had to be assumed accounting for additional variance not covered by the two other factors.

## Association Between Quality and Effect Sizes

### Dataset 1 Back Pain Trials

As reported previously (van Tulder et al., 2009), studies included in the CBRG that scored positive for a quality item reported smaller effect sizes compared with trials that did not fulfill the criterion. The differences were not statistically significant but the included features showed consistency across domains with 10 out of 11 features indicating this effect, as depicted in Table 10.

Table 10 Difference in effect sizes dataset 1 (back pain)

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
Randomization adequate | 104 | 112 | 0.51 | (0.41, 0.61) | 0.49 | (0.40, 0.59) | 0.02 | (-0.12, 0.16)
Allocation concealment | 69 | 147 | 0.45 | (0.33, 0.57) | 0.53 | (0.45, 0.62) | -0.08 | (-0.23, 0.07)
Similar baseline | 135 | 81 | 0.47 | (0.38, 0.55) | 0.57 | (0.45, 0.68) | -0.10 | (-0.24, 0.05)
Assessor blind | 123 | 93 | 0.46 | (0.37, 0.55) | 0.56 | (0.46, 0.67) | -0.10 | (-0.25, 0.04)
Care provider blind | 57 | 159 | 0.43 | (0.30, 0.56) | 0.53 | (0.45, 0.61) | -0.10 | (-0.26, 0.06)
Patient blind | 82 | 134 | 0.48 | (0.37, 0.60) | 0.52 | (0.43, 0.60) | -0.03 | (-0.18, 0.11)
Acceptable dropout rate | 150 | 66 | 0.46 | (0.38, 0.55) | 0.60 | (0.47, 0.73) | -0.13 | (-0.29, 0.02)
Original group (ITT) | 118 | 98 | 0.46 | (0.37, 0.55) | 0.56 | (0.45, 0.67) | -0.10 | (-0.24, 0.04)
Similar cointerventions | 92 | 124 | 0.45 | (0.35, 0.56) | 0.54 | (0.45, 0.63) | -0.09 | (-0.23, 0.05)
Acceptable compliance | 76 | 140 | 0.50 | (0.39, 0.61) | 0.51 | (0.42, 0.59) | -0.01 | (-0.15, 0.14)
Similar timing | 198 | 18 | 0.49 | (0.42, 0.56) | 0.66 | (0.40, 0.92) | -0.17 | (-0.43, 0.10)

ES = effect size; CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat

Figure 9 depicts the difference in effect sizes between studies meeting the individual quality criterion and those that do not. A negative effect size difference indicates possible bias; high-quality studies (those that meet the quality criterion) reported smaller effect sizes.

Figure 9 Difference in effect sizes based on quality features dataset 1 (back pain)

CI = confidence interval; ITT = intention to treat

Figure 9 is a forest plot showing the differences in effect sizes between low and high quality studies for each of the 11 criteria for dataset 1. The forest plot indicates that each lower quality studies reported larger effect sizes based on virtually all quality criteria.

In terms of an established quality measure, differences in effect sizes between low and high quality studies were -0.14 (p<0.05, random effects meta-regression) for items constituting the Jadad scale. High-quality studies reported a mean estimated effect size of 0.45, while low-quality studies reported a mean estimated effect size of 0.60. The fixed-effects model effect size difference was -0.09 (p<0.05).

#### Summary and Factor Scores

To explore a linear effect of quality on effect size, we regressed the effect sizes on a total quality score value which we had computed for each study. The total quality score was obtained by equally weighing each of the 11 quality components to contribute to an overall quality score. The linear effect of the total quality scores across studies was negligible and not statistically significant (-0.04, SE 0.018, p=0.053, 95% CI: -0.073, 0.005).

When effect size was regressed on each of the three factors established in the factor analysis (each factor representing empirical clusters of quality features), the results were also not statistically significant. Standardized effects were for factor 1: 0.07 (p=0.699), factor 2: -0.23 (p=0.077) and factor 3: -0.15 (p=0.245).

Statistically significant results of quality were shown when applying a cutoff of 5 or 6 quality items fulfilled, the difference in effect size between low and high quality studies was 0.20 (van Tulder et. al., 2009). For this analysis, we used a total quality score per study and applied a cutoff empirically distinguishing high- and low-quality studies, depicted in Table 11.

Table 11 Comparison of different quality cutoffs using a total score dataset 1 (back pain)

Cutoff | Number Equal or Above Cutoff | Number Below Cutoff | High Quality | | Low Quality | | Difference
Cutoff | Number Equal or Above Cutoff | Number Below Cutoff | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
≥9 vs <9 | 18 | 198 | 0.46 | (0.23, 0.69) | 0.51 | (0.43, 0.58) | -0.04 | (-0.29, 0.20)
≥8 vs <8 | 42 | 174 | 0.43 | (0.28, 0.58) | 0.52 | (0.44, 0.60) | -0.09 | (-0.26, 0.08)
≥7 vs <7 | 77 | 139 | 0.44 | (0.33, 0.56) | 0.54 | (0.45, 0.63) | -0.10 | (-0.24, 0.05)
≥6 vs <6 | 120 | 96 | 0.42 | (0.33, 0.51) | 0.62 | (0.51, 0.73) | -0.20 | (-0.34, -0.06)^*^
≥5 vs <5 | 145 | 71 | 0.44 | (0.36, 0.52) | 0.64 | (0.52, 0.76) | -0.20 | (-0.35, -0.05)^*^
≥4 vs <4 | 174 | 42 | 0.48 | (0.41, 0.56) | 0.61 | (0.44, 0.77) | -0.13 | (-0.31, 0.06)

* p<0.05

ES = effect size; CI = confidence interval; ESdiff = effect size difference

### Dataset 2 EPC reports

The mean treatment effect across all studies in the EPC report dataset was 0.43 (95% CI: 0.34, 0.53). Few quality features showed differences in effect sizes according to whether these criteria were met as depicted in Table 12. A negative difference indicates that the effect size for the studies fulfilling the criterion is smaller than the effect size for the studies not meeting the criterion. The “no” and “unclear” answers were combined for all initial analyses to increase the number of analyzable studies.

Table 12 Difference in effect sizes dataset 2 (EPC Report)

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
Randomization adequate | 44 | 121 | 0.44 | (0.30, 0.57) | 0.43 | (0.34, 0.51) | 0.01 | (-0.15, 0.17)
Allocation concealment | 38 | 127 | 0.39 | (0.25, 0.53) | 0.45 | (0.36, 0.53) | -0.05 | (-0.22, 0.11)
Similar baseline | 100 | 65 | 0.40 | (0.31, 0.49) | 0.49 | (0.37, 0.61) | -0.09 | (-0.24, 0.05)
Assessor blind | 157 | 8 | 0.43 | (0.36, 0.51) | 0.37 | (0.04, 0.71) | 0.06 | (-0.28, 0.41)
Care provider blind | 120 | 45 | 0.48 | (0.40, 0.56) | 0.29 | (0.15, 0.43) | 0.19 | (0.03, 0.35)^*^
Patient blind | 130 | 35 | 0.47 | (0.40, 0.55) | 0.26 | (0.11, 0.42) | 0.21 | (0.04, 0.39)^*^
Acceptable dropout rate | 96 | 69 | 0.50 | (0.40, 0.59) | 0.35 | (0.24, 0.45) | 0.15 | (0.01, 0.29)^*^
Original group (ITT) | 101 | 64 | 0.45 | (0.36, 0.54) | 0.40 | (0.27, 0.52) | 0.05 | (-0.10, 0.20)
Similar cointerventions | 142 | 23 | 0.44 | (0.36, 0.52) | 0.39 | (0.20, 0.58) | 0.05 | (-0.15, 0.28)
Acceptable compliance | 79 | 86 | 0.44 | (0.34, 0.55) | 0.42 | (0.32, 0.52) | 0.02 | (-0.12, 0.17)
Similar timing | 161 | 4 | 0.44 | (0.37, 0.51) | 0.19 | (-0.24, 0.62) | 0.25 | (-0.19, 0.69)

* p<0.05

EPC = Evidence-based Practice Center; ES = effect size; CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat

High- and low-quality studies showed no difference in effect sizes for several quality features and the direction of possible bias was not consistent across dimensions. This concerned newly proposed quality features as well as established quality criteria such as blinding. For three criteria, a significant difference was found but the effect was discordant with previous studies: when care provider and patients were explicitly blinded, the average effect size in those trials was 0.48 and 0.47 compared to 0.30 and 0.27 in low or unclear quality trials. Studies that reported an acceptable dropout rate had an average effect size of 0.50; studies without description or adequate rate showed a mean effect of 0.35. Figure 10 depicts the direction of effects graphically. The difference in effect size is shown; a negative difference indicates that the high-quality studies in this dataset reported smaller effect sizes.

Figure 10 Difference in effect sizes based on quality features dataset 2 (EPC reports)

CI = confidence interval; ITT = intention to treat

Figure 10 is a forest plot showing the differences in effect sizes for the 11 quality features for dataset 2 (EPC reports). Results varied across criteria with sometimes lower quality studies reporting larger effect sizes and sometimes showing the reverse effect.

Using the items constituting the Jadad scale (randomization, blinding, and dropouts), differences in effect sizes between low- and high-quality studies were 0.09 (n.s., random effects meta-regression). High-quality studies reported an effect size of 0.45 while low quality reported an effect size of 0.35 across studies. Using a fixed-effects model, the mean effect sizes were 1.07 versus 0.13 (overall effect size difference 0.94, p<0.05). The fixed-effects analysis is particularly affected by outliers. When excluding those three studies with extremely high and unmatched results, effect size differences were still 0.29. All analyses indicated that in this dataset there was no statistically significant difference in high- and low-quality studies, and often high-quality studies reported somewhat larger treatment effects, hence opposite to what we expected to find.

As shown earlier, in this dataset there was a high number of “unclear” answers. To investigate whether the combination of “no's” and “unclear's” may have distorted the effects of quality, we estimated the results separately, and compared the explicit negative and the unclear cases to the cases where the feature was explicitly present, that is, the criterion was clearly met, as depicted in Table 13.

Table 13 Criterion met versus not met and versus unclear (EPC reports)

Quality Feature | Met | Not | Unclear | Difference Criterion Met Versus Not Met | | Difference Criterion Met Versus Unclear | | Difference Criterion Met or Unclear Versus Not Met
Quality Feature | Met | Not | Unclear | ESdiff | 95% CI | ESdiff | 95% CI | ESdiff | 95% CI
Randomization adequate | 44 | 7 | 114 | 0.23 | (-0.19, 0.65) | 0.00 | (-0.16, 0.16) | 0.23 | (-0.17, 0.64)
Allocation concealment | 38 | 4 | 123 | 0.35 | (-0.20, 0.90) | -0.07 | (-0.23, 0.10) | 0.40 | (-0.14, 0.93)
Similar baseline | 100 | 17 | 48 | -0.10 | (-0.35, 0.14) | -0.09 | (- 0.25, 0.07) | -0.07 | (-0.31, 0.16)
Assessor blind | 157 | 2 | 6 | -0.93 | (-1.57, -0.30)^*^ | 0.40 | (0.02, 0.78)^*^ | -0.94 | (-1.58, -0.30)^*^
Care provider blind | 120 | 33 | 12 | 0.11 | (-0.07, 0.30) | 0.38 | (0.11, 0.65)^*^ | 0.08 | (-0.11, 0.26)
Patient blind | 130 | 31 | 4 | 0.19 | (0.01, 0.36)^*^ | 0.38 | (-0.05, 0.80) | 0.18 | (-0.01, 0.36)
Acceptable dropout rate | 96 | 65 | 4 | 0.14 | (-0.01, 0.28) | 0.33 | (-0.13, 0.78) | 0.13 | (-0.02, 0.27)
Original group (ITT) | 101 | 10 | 54 | 0.08 | (-0.24, 0.39) | 0.05 | (-0.11, 0.21) | 0.06 | (-0.25, 0.37)
Similar cointerventions | 142 | 5 | 19 | -0.17 | (-0.59, 0.25) | 0.11 | (-0.12, 0.34) | -0.18 | (-0.60, 0.24)
Acceptable compliance | 79 | 8 | 78 | 0.25 | (-0.06, 0.47) | -0.01 | (-0.15, 0.14) | 0.26 | (-0.05, 0.56)
Similar timing | 161 | 4 | 0 | 0.25 | (-0.19, 0.69) | NA | NA | 0.25 | (-0.19, 0.69)

* p<0.05

EPC = Evidence-based Practice Center; ESdiff = effect size difference; CI = confidence interval; ITT = intention to treat

When combining high-quality studies and studies rated as unclear, thereby giving the benefit of the doubt, the sample sizes for negative studies are very small. This stratified analysis showed that the lack of association of the feature with effect sizes cannot be generally explained by the combination of explicitly negative and unclear answers.

We also investigated in this dataset whether the conversion of dichotomous outcomes to effect sizes that was necessary in some studies may have influenced the associations between quality features and study results. Only considering original continuous outcomes, the differences between low and high quality studies ranged from -0.12 (similar baseline) to 0.33 (similar timing of outcome assessment) where a negative difference indicates that the studies with the feature showed smaller effect sizes. The 0.33 difference was based on 3 studies only where the similar outcome assessment criterion was not met or remained unclear.

#### Summary and Factor Scores

To explore a linear effect of quality on effect size, we again regressed the effect sizes on the total quality score values. The effect of the total quality scores weighting each item equally was negligible and not significant (0.02; p=0.233, 95% CI: -0.015, 0.062).

We also used the established factor scores that group similar items in terms of inter-item correlations as well as associations with effect sizes. Differential trends shown for the individual items as seen in the table above should become apparent using these factor empirically derived item clusters. Raw effect size (not accounting for precision with any weights) was regressed on the established factors. High-loading items from factor 1 (adequate randomization sequence, allocation concealment) were not statistically significantly associated with effect sizes (-0.172, 95% CI: -0.41, 0.06; p=0.15), nor was describing an acceptable dropout rate which mainly contributed factor 3 (0.14; 95% CI: -0.06, 0.49; p=0.16). The two blinding items and the ITT item that constitute factor 2 showed a statistically significant influence (but unexpected directionality) on effect sizes (0.24, 95% CI: 0.04, 0.44; p=0.02).

As depicted in Table 14, when comparing studies with high or low quality and applying different cutoffs, we found a marginal significant difference in effect sizes for five or more quality criteria met. However, the direction of effects was opposite to what we found in the back pain trials: high quality studies reported larger treatment effects. There was no indication that low-quality studies overestimated treatment effects; in this dataset the high-quality RCTs reported larger effects. Appendix D shows the results based on a fixed-effects model (this analysis results in smaller confidence intervals and several significant results, but the analysis is more affected by outliers).

Table 14 Comparison of different quality cutoffs using a total score (EPC reports)

Cut-off | Number Equal or Above Cutoff | Number Below Cutoff | High Quality | | Low Quality | | Difference
Cut-off | Number Equal or Above Cutoff | Number Below Cutoff | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
≥9 vs <9 | 42 | 123 | 0.54 | (0.40, 0.67) | 0.39 | (0.31, 0.47) | 0.15 | (-0.01, 0.30)
≥8 vs <8 | 65 | 100 | 0.45 | (0.34, 0.56) | 0.42 | (0.32, 0.51) | 0.03 | (-0.11, 0.18)
≥7 vs <7 | 103 | 62 | 0.43 | (0.35, 0.52) | 0.43 | (0.31, 0.55) | 0.01 | (-0.14, 0.16)
≥6 vs <6 | 135 | 30 | 0.46 | (0.38, 0.53) | 0.30 | (0.12, 0.47) | 0.16 | (-0.03, 0.35)
≥5 vs <5 | 149 | 16 | 0.45 | (0.38, 0.53) | 0.18 | (-0.06, 0.42) | 0.27 | (0.02, 0.52)^*^
≥4 vs <4 | 160 | 5 | 0.44 | (0.37, 0.51) | 0.04 | (-0.39, 0.46) | 0.41 | (-0.02, 0.84)

* p<0.05

EPC = Evidence-based Practice Center; ES = effect size; CI = confidence interval; ESdiff = effect size difference

The above table also clearly demonstrates the imbalance of this dataset. There were very few low-quality studies in this dataset. When comparing studies that only reached 4 out of 11 possible quality scores, only 5 studies could be included in the analysis.

### Dataset 3 Published “Pro-bias” Dataset

Given the discrepant results between the analyses of the back pain dataset and the EPC reports dataset, we decided to add a third dataset. We were struck, in particular, by the observation that in the EPC dataset for the majority of quality features we actually found results in the opposite direction as expected from prior research (high-quality studies reported larger effect sizes). As outlined in the method section for our third dataset, we therefore determined that we should use one where established criteria such as the Jadad and Schulz items had known values in the expected direction. For that reason, we decided to use a replication of the dataset used by Moher and colleagues in their original validation of these quality features.

As opposed to the prior two datasets, all the outcomes in this dataset used dichotomous outcomes. Therefore, instead of a difference in effect sizes we use, as Moher and colleagues did in their original analysis, the odds ratio as the measure of effect and the ratio of odds as assessment of the effect of a quality criterion across studies. The overall odds ratio across studies was 0.47 (95% CI: 0.42, 0.52). An odds ratio below 1 indicates the treatment group is doing better than the control.

In this dataset we also applied the full Jadad scale and the criteria proposed by Schulz (1995), which included concealment of allocation using the original scoring instructions. We compared adequate randomization (score=2 versus <2), blinding (score=2 versus <2) and withdrawals (score 1 versus 0) and a total score of 3 or more (out of 5) compared to less than 3 for the total Jadad score. For the Schulz scores, we compared criterion met versus not met or unclear. Table 15 shows the results for these established quality criteria.

Table 15 Difference in odds ratios for Jadad and Schulz criteria

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | OR | 95% CI | OR | 95% CI | ROR | 95% CI
Random Effects Meta-regression
Jadad: randomization=2 | 33 | 67 | 0.48 | (0.36, 0.57) | 0.45 | (0.35, 0.57) | 0.95 | (0.62, 1.44)
Jadad: blinding=2 | 36 | 64 | 0.43 | (0.31, 0.61) | 0.47 | (0.37, 0.60) | 1.08 | (0.72, 1.64)
Jadad: withdrawals=1 | 74 | 26 | 0.48 | (0.38, 0.60) | 0.41 | (0.29, 0.60) | 0.87 | (0.56, 1.34)
Jadad: total≥3 | 62 | 38 | 0.46 | (0.36, 0.60) | 0.45 | (0.33, 0.61) | 0.97 | (0.65, 1.45)
Schulz: concealment | 26 | 74 | 0.58 | (0.40, 0.86) | 0.42 | (0.34, 0.53) | 0.72 | (0.46, 1.13)
Schulz: sequence | 30 | 70 | 0.45 | (0.31, 0.65) | 0.46 | (0.36, 0.58) | 1.01 | (0.66, 1.56)
Schulz: analysis | 41 | 59 | 0.50 | (0.37, 0.68) | 0.43 | (0.33, 0.55) | 0.85 | (0.57, 1.26)
Schulz: blinding | 66 | 34 | 0.44 | (0.34, 0.56) | 0.50 | (0.35, 0.69) | 1.13 | (0.74, 1.71)
Fixed Effects Model
Jadad: randomization=2 | 33 | 67 | 0.51 | (0.43, 0.61) | 0.45 | (0.40, 0.51) | 0.88 | (0.70, 1.09)
Jadad: blinding=2 | 36 | 64 | 0.45 | (0.37, 0.54) | 0.47 | (0.42, 0.53) | 1.05 | (0.85, 1.31)
Jadad: withdrawals=1 | 74 | 26 | 0.52 | (0.46, 0.59) | 0.39 | (0.33, 0.46) | 0.74 | (0.60, 0.92)^*^
Jadad: total≥3 | 62 | 38 | 0.51 | (0.44, 0.58) | 0.43 | (0.37, 0.49) | 0.85 | (0.69, 1.03)
Schulz: concealment | 26 | 74 | 0.57 | (0.46, 0.69) | 0.44 | (0.39, 0.49) | 0.77 | (0.61, 0.97)^*^
Schulz: sequence | 30 | 70 | 0.50 | (0.41, 0.60) | 0.46 | (0.41, 0.51) | 0.92 | (0.74, 1.15)
Schulz: analysis | 41 | 59 | 0.51 | (0.44, 0.59) | 0.43 | (0.38, 0.50) | 0.85 | (0.70, 1.04)
Schulz: blinding | 66 | 34 | 0.48 | (0.42, 0.55) | 0.44 | (0.38, 0.52) | 0.92 | (0.75, 1.12)

* p<0.05

OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios

As the original paper by Moher and colleagues does not specify whether they used a fixed-effects or a random-effects model, we present the results in Table 15 using both methods. Our fixed-effect results come closest to the original results presented by Moher et al. (1998). The dimensions overall showed consistent results, with the ratio of odds ratios (ROR) for low-quality studies compared to high-quality studies being less than 1, meaning high-quality studies reported smaller treatment effects (i.e., larger ORs) than did low-quality studies. Using a fixed-effects model, the concealment criterion item of Schulz is statistically significantly associated with smaller treatment effects, and the Jadad scale is nearly so (ROR = 0.85, 95% CI: 0.69, 1.03). Using the random effects model, both point estimates go in the expected direction, but neither result is statistically significantly different from an ROR of 1.

Table 16 shows the odds ratios of studies where the criterion is met and odds ratios for studies where the criterion is not met, either because of poor reporting or due to the design, conduct, or analysis of the individual study, using a fixed-effects model. The corresponding results using a meta-regression model assuming random effects are shown in Appendix E. To assess the difference between these two study types, we estimated an ROR. Again, an ROR less than 1 indicated that the studies that did not meet the quality criteria had a better treatment effect than those studies that met the quality criteria.

Table 16 Difference in odds ratios for proposed quality criteria dataset 3 (“pro-bias”)

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | OR | 95% CI | OR | 95% CI | ROR | 95% CI
Randomization adequate | 34 | 66 | 0.49 | (0.41, 0.59) | 0.46 | (0.41, 0.52) | 0.94 | (0.75, 1.17)
Allocation concealment | 26 | 74 | 0.50 | (0.41, 0.62) | 0.46 | (0.41, 0.51) | 0.91 | (0.72, 1.14)
Similar baseline | 36 | 64 | 0.47 | (0.40, 0.56) | 0.46 | (0.41, 0.52) | 0.98 | (0.80, 1.21)
Assessor blind | 78 | 22 | 0.44 | (0.39, 0.49) | 0.59 | (0.47, 0.74) | 1.35 | (1.05, 1.73)
Care provider blind | 69 | 31 | 0.50 | (0.41, 0.57) | 0.41 | (0.35, 0.49) | 0.83 | (0.67, 1.02)
Patient blind | 72 | 28 | 0.47 | (0.42, 0.53) | 0.46 | (0.38, 0.55) | 0.97 | (0.78, 1.21)
Acceptable dropout rate | 62 | 38 | 0.54 | (0.47, 0.62) | 0.39 | (0.34, 0.46) | 0.72 | (0.59, 0.88)
Original group (ITT) | 29 | 71 | 0.49 | (0.42, 0.58) | 0.45 | (0.40, 0.51) | 0.91 | (0.74, 1.12)
Similar cointerventions | 68 | 32 | 0.40 | (0.35, 0.46) | 0.60 | (0.51, 0.71) | 1.50 | (1.22, 1.85)
Acceptable compliance | 46 | 54 | 0.56 | (0.48, 0.66) | 0.41 | (0.36, 0.46) | 0.72 | (0.59, 0.88)
Similar timing | 89 | 11 | 0.45 | (0.41, 0.50) | 0.60 | (0.43, 0.84) | 1.33 | (0.94, 1.88)

OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios; ITT = intention to treat

The direction of effects for the 11 quality features was not uniform but for the majority of quality domains the low quality studies reported smaller odds ratios thereby overestimating the treatment effect. Differences between low- and high-quality studies were statistically significant for the quality items assessor blinding, acceptable dropout rate, similar cointerventions, and acceptable compliance. Figure 11 below displays the effects graphically.

Figure 11 Ratio of odds ratio based on quality features dataset 3 (“pro-bias”), FE

FE = based on fixed-effects model; CI = confidence interval; ITT = intention to treat

Figure 11 is a forest plot showing the differences in effect sizes between low and high quality studies for each quality features in dataset 3 (‘pro-bias’). The direction of effects was not uniform but for the majority of quality domains the low quality studies reported smaller odds ratios thereby overestimating the treatment effect. The analysis is based on a fixed effects model and the figure depicts smaller confidence intervals than the other forest plots.

#### Summary and Factor Scores

We also computed total quality scores for each study based on the 11 assessed quality features. Using this summary score and regressing effect size on quality, thereby assuming a linear relationship between the two variables, we find no statistically significant effect (estimate = 0.033, p=0.486, 95% CI: -0.061, 0.127) for total quality, regardless of the employed meta-regression model.

Using the factor scores that group related items, in terms of intercorrelations as well as in their strength of association with study results (the MIMIC model) we can show differences in groups of quality measures. The regression effect of log odds ratios on the randomization factor (high loadings in this dataset: adequate randomization sequence generation, concealed treatment allocation; Factor 1) was 0.05, and was not significant (p=0.792). The effect of the blinding factor (high loadings in this dataset: provider blind, patient blind, assessor blind) was also not statistically significant (-0.06, p = 0.71), again regardless of the employed method. Factor 3 (high loadings in this dataset: acceptable dropout rate, similar baseline, original group (ITT), similar cointerventions, and similar timing) had a marginally nonsignificant, and negative effect on the log odds ratios (-0.22, p=0.07).

When comparing studies with high or low quality, and applying different cutoffs, and applying the proposed quality criteria of the Cochrane back review group to compute a total score, we find that based on a fixed-effects model, a cutoff of 5 or 6 differentiates the studies statistically significant as shown in Table 17.

Table 17 Comparison of different quality cutoffs using a total score dataset 3 (“pro-bias”)

Cut-off | Number Equal or Above Cutoff | Number Below Cutoff | High Quality | | Low Quality | | Difference
Cut-off | Number Equal or Above Cutoff | Number Below Cutoff | OR | 95% CI | OR | 95% CI | ROR | 95% CI
≥9 vs <9 | 14 | 86 | 0.43 | (0.32, 0.57) | 0.47 | (0.42, 0.52) | 1.09 | (0.81, 1.46)
≥8 vs <8 | 26 | 74 | 0.53 | (0.43, 0.64) | 0.45 | (0.40, 0.50) | 0.85 | (0.68, 1.07)
≥7 vs <7 | 44 | 56 | 0.45 | (0.39, 0.53) | 0.48 | (0.42, 0.54) | 1.05 | (0.86, 1.29)
≥6 vs <6 | 62 | 38 | 0.52 | (0.45, 0.59) | 0.40 | (0.34, 0.47) | 0.77 | (0.63, 0.95)^*^
≥5 vs <5 | 76 | 24 | 0.50 | (0.44, 0.56) | 0.39 | (0.32, 0.48) | 0.79 | (0.63, 0.99)^*^
≥4 vs <4 | 86 | 14 | 0.48 | (0.43, 0.54) | 0.40 | (0.32, 0.50) | 0.83 | (0.65, 1.07)

* p<0.05

OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios

High-quality studies show less pronounced treatment effects compared to low-quality studies. The equivalent analysis using a random effects meta-regression is reported in Appendix E. Using this model, a cutoff of 7 differentiates high- and low-quality studies best, but this result does not reach statistical significance.

### Comparison Across Datasets

Figure 12 allows a comparison of observed indicators of bias for each individual quality feature across datasets.

Figure 12 Differences in effect sizes across datasets

Left to right: back pain data, EPC reports, “pro-bias” (fixed-effects model), “pro-bias” (random-effects model)

ITT = intention to treat

Figure 12 depicts all three previous forest plots to enable a comparison between datasets. In addition to the fixed effects model the results of the random effects model is also shown for dataset 3.

While the back pain dataset shows small but consistent results across quality criteria indicating that studies fulfilling the quality criterion report smaller effect sizes, the EPC dataset indicate for the majority of quality dimensions that high-quality studies reported larger treatment effects. The third dataset shows the most variation across quality criteria. In the fixed-effects analysis, the differences across high- and low-quality studies reach statistical significance.

Only allocation concealment showed consistent results across datasets. Unconcealed trials reported larger effect sizes in the back pain dataset (effect size difference in random effects meta-regression -0.08 (95% CI: -0.23, 0.07) and the EPC report dataset (effect size difference in random effects meta-regression -0.06 (95% CI: -0.22, 0.11), and the ratio of odds ratios in the third dataset also showed that unconcealed trials reported larger treatment effects (ROR=0.91, 95% CI: 0.72, 1.14).This analysis indicates that unconcealed trials tend to overestimate the treatment effect.

Across all three datasets, there was no statistically significant linear effect of quality on effect sizes. Regression models could not show that the effect size decreased linearly with increasing total quality scores.

The factors derived through factor analysis showed no statistically significant association between quality and effect sizes. One exception was the blinding/ITT factor (factor 2 in the EPC report data), but here with unexpected directionality (larger effects observed in high-quality studies).

Comparing different cutoffs shows that five or more fulfilled criteria differentiate high- and low-quality studies best across datasets. In dataset 1 (back pain), the difference between effect sizes was -0.20 for both, five criteria fulfilled or more (95% CI: -0.34, -0.06), and six criteria fulfilled or more (95% CI: -0.35, -0.05). In the third dataset, the ratio of odds ratios was 0.79 (95% CI: 0.63, 0.95) and 0.77 (95% CI: 0.63, 0.99) respectively for five and six criteria met (based on a fixed-effects model). In both cases, low-quality studies overestimated treatment effects. However, in the EPC report dataset, a cutoff of five or more quality criteria met also resulted in a statistically significant result (effect size difference 0.27, 95% CI: 0.02, 0.52), but the direction was opposite to our expectations. Low-quality studies did not overestimate treatment effects but reported smaller effect sizes than high-quality trials in this dataset.

## Why the Association Between Quality Features and Effect Sizes Might Vary Across Datasets: Moderators and Confounders

As seen above, the association between quality features and effect sizes varies across the three employed datasets. In two of the datasets, the Jadad and Schulz criteria show associations that are consistent with that found by others, namely that higher quality studies have smaller estimates of effect. In these two datasets, the CBRG internal validity items also, in general, show the predicted relationships between quality and effect size, and in each a summary score of the 11 items is useful for distinguishing high- and low-quality trials (cutoff 5 to 7 quality items met). However, in the EPC dataset, the majority of quality features show either no relationship or a paradoxical relationship with effect size. To try and understand why these differences might exist, we undertook an analysis looking at moderators and confounders based on our conceptual models outlined in the method section.

We wanted to investigate the effect of the size of the treatment effect, the effect of the condition being treated, the effect of the type of outcome, and the effect of the observed variance in quality features.

### Variable 1 Size of Treatment Effect

One variable we pursued was the size of the treatment effect reported in each individual meta-analysis. Our hypothesis was that if a treatment is very effective, this may minimize any associations between quality and outcomes. Depending on the type of intervention, the achieved effect can vary systematically across studies, thereby possibly confounding an effect of the association of quality and study results across studies. We added the treatment effect observed in each individual meta-analysis to the regression model.

Table 18 shows the differences between low- and high-quality studies for the EPC report dataset when controlling for the mean treatment effect in each meta-analysis.

Table 18 Controlling for size of treatment effect dataset 2 (EPC reports)

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
Randomization adequate | 44 | 121 | 0.41 | (0.31, 0.51) | 0.41 | (0.35, 0.48) | 0.00 | (-0.12, 0.11)
Allocation concealment | 38 | 127 | 0.40 | (0.29, 0.50) | 0.42 | (0.36, 0.48) | -0.02 | (-0.14, 0.10)
Similar baseline | 100 | 65 | 0.40 | (0.31, 0.46) | 0.44 | (0.35, 0.53) | -0.04 | (-0.16, 0.07)
Assessor blind | 157 | 8 | 0.41 | (0.35, 0.46) | 0.53 | (0.28, 0.79) | -0.13 | (-0.39, 0.13)
Care provider blind | 120 | 45 | 0.40 | (0.34, 0.47) | 0.44 | (0.33, 0.55) | -0.03 | (-0.17, 0.10)
Patient blind | 130 | 35 | 0.41 | (0.35, 0.47) | 0.42 | (0.30, 0.55) | -0.01 | (-0.16, 0.13)
Acceptable dropout rate | 96 | 69 | 0.41 | (0.34, 0.48) | 0.42 | (0.33, 0.50) | 0.00 | (-0.12, 0.11)
Original group (ITT) | 101 | 64 | 0.41 | (0.34, 0.47) | 0.43 | (0.33, 0.52) | -0.02 | (-0.14, 0.10)
Similar cointerventions | 142 | 23 | 0.41 | (0.35, 0.47) | 0.43 | (0.28, 0.57) | -0.02 | (-0.18, 0.14)
Acceptable compliance | 79 | 86 | 0.40 | (0.33, 0.48) | 0.42 | (0.35, 0.50) | -0.02 | (-0.13, 0.09)
Similar timing | 161 | 4 | 0.42 | (0.36, 0.47) | 0.30 | (-0.02, 0.62) | 0.12 | (-0.21, 0.44)

ES = effect size; CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat

There is no indication that controlling for treatment effect size reveals associations of quality and effect sizes. In fact, controlling for this variable eliminates differences between high- and low-quality studies, effect size differences range around zero. The differential effect of possible bias (sometimes indicating that low-quality studies show larger effect sizes than high-quality studies, sometimes indicating that high-quality studies show larger effect sizes) that characterizes the EPC report dataset appears to be primarily based on this treatment effect variable.

A similar result was observed in the third dataset, which showed similar results overall to the original back pain results. The differences in effect sizes comparing high- and low-quality studies are negligible for several quality domains with the exception of reported provider blinding, acceptable dropout rate and the ITT item (original group) when comparing for size of treatment effect, as shown in Table 19.

Table 19 Controlling for size of treatment effect dataset 3 (“pro-bias”)

Quality Feature | Number Criterion Met | Number Criterion Not Met | OR in Trials With Criterion Met | | OR in Trials With Criterion Not Met | | OR Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | OR | 95% CI | OR | 95% CI | ROR | 95% CI
Randomization adequate | 34 | 66 | 0.44 | (0.31, 0.63) | 0.46 | (0.37, 0.59) | 1.02 | (0.72, 1.43)
Allocation concealment | 26 | 74 | 0.42 | (0.31, .0.58) | 0.44 | (0.37, 0.52) | 1.04 | (0.72, 1.49)
Similar baseline | 36 | 64 | 0.44 | (0.34, 0.57) | 0.44 | (0.36, 0.53) | 0.99 | (0.72, 1.35)
Assessor blind | 78 | 22 | 0.44 | (0.37, 0.52) | 0.44 | (0.31, 0.62) | 0.99 | (0.67, 1.47)
Care provider blind | 69 | 31 | 0.48 | (0.40, 0.57) | 0.36 | (0.28, 0.47) | 0.75 | (0.55, 1.02)
Patient blind | 72 | 28 | 0.44 | (0.37, 0.520 | 0.43 | (0.33, 0.58) | 0.99 | (0.70, 1.39)
Acceptable dropout rate | 62 | 38 | 0.50 | (0.41, 0.61) | 0.38 | (0.30, 0.47) | 0.75 | (0.56, 1.00)
Original group (ITT) | 29 | 71 | 0.53 | (0.41, 0.67) | 0.39 | (0.33, 0.47) | 0.74 | (0.55, 1.01)
Similar cointerventions | 68 | 32 | 0.42 | (0.35, 0.51) | 0.47 | (0.36, 0.61) | 1.12 | (0.81, 1.55)
Acceptable compliance | 46 | 54 | 0.46 | (0.37, 0.58) | 0.42 | (0.34, 0.51) | 0.91 | (0.67, 1.24)
Similar timing | 89 | 11 | 0.44 | (0.37, 0.52) | 0.42 | (0.25, 0.70) | 0.96 | (0.56, 1.64)

OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios; ITT = intention to treat

Using summary quality scores and regressing study results on quality, we find in both new datasets no significant results that indicate a significant linear relationship between these two variables. When controlling for the mean treatment effect of each of the 12 meta-analyses in the EPC reports dataset, the regression results are still -0.02 (p=0.38; 95% CI: -0.06, 0.02) as opposed to 0.02. When controlling for the mean effect size of each of the 11 meta-analyses in the third dataset, results are also unchanged: 0.04 (p=0.376; 95% CI: -0.05, 0.13), previously 0.03.

### Variable 2 Condition Being Treated

In the EPC report dataset, we found no clear associations between quality and effect size across all studies. Hence, we wanted to investigate whether pooling across meta-analyses masks associations between the quality features and effect sizes. In order to see whether the associations between quality and effect sizes are consistent or notably different across clinical fields, we stratified the studies by the condition being treated or the clinical field. Only this dataset was considered suitable for this analysis (see method section).

Table 20 shows the effect size difference for high- (criterion fulfilled) and low- (criterion not fulfilled) quality studies for each meta-analysis individually for the EPC report dataset studies. Each cell had to have at least three trials with the feature present versus absent or unclear to be estimated.

Table 20 Effect size differences studies fulfilling criterion versus not by clinical field (EPC reports)

Quality Feature | Alzheimer's | Arthritis | CDSM | Chromium | Epilepsy | Glucosamine | OCD | Omega 3 | Orlistat | SAMe | SMBG | Vitamin E
Randomization adequate | .04 | n/a | -0.08 | n/a | .00 | -.10 | -.12 | -.01 | .32 | -.03 | n/a | -.17
Allocation concealment | .07 | n/a | -0.26 | n/a | .00 | -.19 | -.53 | .01 | .32 | n/a | n/a | .3
Similar baseline | .08 | n/a | -0.04 | -.47 | -.11 | -.20 | .28 | -.10 | n/a | -.53 | .18 | -.41
Assessor blind | n/a | n/a | n/a | n/a | n/a | n/a | n/a | -.02 | n/a | n/a | n/a | .36
Care provider blind | n/a | n/a | n/a | n/a | n/a | .14 | n/a | .00 | n/a | n/a | n/a | .14
Patient blind | n/a | n/a | n/a | n/a | n/a | n/a | n/a | -.06 | n/a | n/a | n/a | n/a
Acceptable dropout rate | -.12 | n/a | -0.03 | .36 | -.05 | .09 | n/a | .10 | .01 | -1.39 | -.01 | .38
Original group (ITT) | n/a | n/a | 0.31 | -.45 | -.04 | -.12 | .12 | -.02 | -.04 | -.85 | -.05 | .25
Similar cointerventions | n/a | n/a | 0.04 | n/a | .17 | -1.02 | .79 | -.23 | n/a | n/a | .13 | n/a
Acceptable compliance | n/a | n/a | 0.01 | .45 | -.03 | -.37 | .18 | -.15 | -.02 | .17 | .1 | -.02
Similar timing | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | n/a | .22 | n/a

EPC = Evidence-based Practice Center; n/a = not available (fewer than three trials in each group); ITT = intention to treat; CDSM: chronic disease self-management; OCD: obsessive-compulsive-disorder; SAMe: S-adenosylmethionine; SMBG: self-monitoring of blood glucose

The table shows that in each meta-analysis, many comparisons could not be computed due to lack of variance across studies in these smaller units. Very often there was not enough information to judge the criterion, meaning fewer than three studies in each meta-analysis scored definitely positive. For some quality features (e.g., was the timing of outcome assessment similar in both groups) there were no studies not meeting this criterion, so again the difference in effect sizes could not be computed.

There was no clear support for the hypothesis of the condition being treated masking the associations of quality through pooling. The quality effects were not confounded as outlined in the method section; the pooling appeared to cancel out conflicting effects across fields resulting in the negligible pooled effects seen. The effect of the quality features varied across clinical fields in that a quality criterion that was met sometimes indicated smaller effect sizes and sometimes larger effect sizes. For example, in most fields, the adequacy of randomization sequence showed a small difference between high- and low-quality studies in the direction that the high-quality studies reported smaller effect sizes, but the direction of effect was reversed for the orlistat trials. Most consistency in the expected effect (smaller effect sizes when quality criterion met) was found for randomization sequence adequate, similar baseline, ITT analysis, and acceptable compliance.

In addition, we repeated this analysis using a total quality score that considered all assessed quality features. Again, it is possible that the type of condition acts as a moderator or confounder. In some studies quality may have an effect on study results, but these effects are masked by other studies where there is no association between quality and study results. The effect of the total quality sum score on study results was calculated for each condition. The meta-regression slopes for each condition are shown in Table 21 and Figure 13.

Table 21 Total quality regressed on effect size (EPC reports)

Condition | Estimate | SE
1. Alzheimer's | 0.01 | 0.08
2. Arthritis | 0.38 | 0.40
3. CDSM | -0.02 | 0.06
4. Chromium | -0.35 | 0.18
5. Epilepsy | -0.01 | 0.06
6. Glucosamine | -0.10 | 0.07
7. OCD | -0.04 | 0.07
8. Omega 3 | -0.03 | 0.04
9. Orlistat | 0.05 | 0.06
10. SAMe | -0.14 | 0.12
11. SMBG | 0.03 | 0.06
12. Vitamin E | 0.09 | 0.12

EPC = Evidence-based Practice Center; SE = standard error; CDSM: chronic disease self-management; OCD: obsessive-compulsive-disorder; SAMe: S-adenosylmethionine; SMBG: self-monitoring of blood glucose

Figure 13 Meta-regression slopes showing relationship between total quality and effect size in each type of study

Circle is proportional to the size of the study; the line represents the effect on effect size.

Figure 13 shows the meta-regression slopes between total quality and effect size in each of the 12 meta-analyses included in dataset 2 (EPC reports). In the scatter plots the circle is proportional to the size of the study. The line represents the effect on effect size. The slopes appear to be different visually, but as the text underneath the figure outlines, the slopes are not statistically significantly different from each other.

The interaction effect of condition by total quality was not statistically significant (p=0.574), meaning that slopes are not significantly different from each other indicating that condition is not a moderator (confounder) of the association between quality and effect sizes.

### Variable 3 Type of Outcome

Table 22 shows differences of studies fulfilling a quality criterion compared to studies not meeting the criterion when controlling for the type of outcome, that is, objective or less prone to measurement error, versus other outcomes. In dataset 2 (EPC reports), 47 studies were classified as having an objective outcome as opposed to other endpoints; in the third dataset there were 35 studies (the back pain dataset did not include objective outcomes).

Table 22 Difference in effect sizes between high- and low-quality studies, controlled for type ofoutcome

Quality feature | EPC reports | | Published dataset
Quality feature | ESdiff | 95% CI | ROR | 95% CI
Randomization adequate | 0.01 | (-0.14, 0.15) | 1.12 | (0.74, 1.70)
Allocation concealment | -0.05 | (-0.20, 0.10) | 1.02 | (0.65, 1.60)
Similar baseline | -0.01 | (-0.15, 0.12) | 1.03 | (0.67, 1.59)
Assessor blind | -0.06 | (-0.38, 0.25) | 1.27 | (0.78, 2.06)
Care provider blind | -0.14 | (-0.32, 0.05) | 0.71 | (0.46, 1.10)
Patient blind | -0.16 | (-0.37, 0.05) | 0.66 | (0.40, 1.08)
Acceptable dropout rate | 0.08 | (-0.05, 0.21) | 0.83 | (0.56, 1.22)
Original group (ITT) | -0.10 | (-0.24, 0.05) | 0.91 | (0.60, 1.37)
Similar cointerventions | -0.05 | (-0.24, 0.13) | 1.24 | (0.82, 1.89)
Acceptable compliance | -0.02 | (-0.15, 0.11) | 0.76 | (0.52, 1.12)
Similar timing | 0.09 | (-0.32, 0.49) | 0.74 | (0.36, 1.51)

EPC = Evidence-based Practice Center; ESdiff = effect size difference; CI = confidence interval; ROR = ratio of odds ratios; ITT = intention to treat

For most individual quality domains differences between high- and low-quality studies were not more pronounced when controlling for the type of outcome. Controlling for the type of outcome, the association between a total quality score and reported effect size is 0.01 (SE 0.02) in the EPC reports and 0.02 (SE 0.05) in the “pro-bias” dataset.

In a moderator analysis, an interaction effect between total quality and the type of outcome measure was investigated. The slope of total quality for studies with nonobjective outcomes in the EPC report sample was 0.02 (95% CIs -0.03, 0.06; p=0.446). For studies with objective outcomes, the slope was -0.01 (95% CIs: -0.08, 0.05; p=0.639). The difference in slopes was not statistically significant (0.03; 95% CIs: -0.04, 0.10; p=0.411). Figure 14 shows the difference between these effects.

Figure 14 Association quality – effect size, moderator type of outcome (EPC reports)

Green circles and line represent objective outcomes, red represent nonobjective outcomes.

Figure 14 is a scattered plot plotting the association between quality and effect size for studies with an objective outcome and for studies with other outcomes in the dataset 2 (EPC reports). Visually the slopes appear to differ but as the text above the figure outlines, not statistically significantly.

In the third dataset, the slope for nonobjective studies was -0.026 (SE 0.06; p=0.686); the slope for objective studies was 0.00 (SE 0.08; p=0.997). The interaction effect, the difference between these slopes was not statistically significant (0.026; SE 0.10; p=0.80). Figure 15 graphically depicts the effects of the type of outcome as a moderator, indicating a slightly different, that is, not parallel slope for the two types of studies.

Figure 15 Association quality – effect size, moderator type of outcome (“pro-bias”)

Figure 15 is a scattered plot plotting the association between quality and effect size for studies with an objective outcome and for studies with other outcomes in the dataset 3 (‘pro-bias’). Visually the slopes appear to differ but as the text above the figure outlines, not statistically significantly.

### Variable 4 Variance in Effect Sizes

In order to test the hypothesis that the variance in effect sizes explains differences between datasets, we compared the effect size distribution across datasets. Figures 16 and 17 show the distribution of the effect sizes reported for each included study in the three datasets.

Figure 16 Effect size distribution dataset 1

Back pain data, absolute values on the right

Figure 16 shows two column graphs representing the effect size distribution in dataset 1 expressed as original effects or as absolute values. The distribution approaches a normal distribution.

Figure 17 Effect size distribution dataset 2 (EPC reports) and dataset 3 (“pro-bias”)

Figure 17 shows two column graphs representing the effect size distribution in dataset 2 and 3. The distributions shown in figure 16 and 17 differ considerably which is further outlined in the text below the figure as follows: The three datasets show different distributions of effect sizes. The back pain and the published ‘pro-bias’ data stem from datasets with substantial variation in reported effect sizes and approaching a symmetric distribution. The effect size distribution in the EPC report dataset was restricted, most reported results were small and very few were negative.

The distribution of effect sizes in the original back pain articles was approaching a normal distribution. The analyses presented in this report are based on absolute values but the quality effect size association results are very similar when using the original reported effect sizes. The effect size distribution of the other publications is shown in Figure 17.

The three datasets show different distributions of effect sizes. The back pain and the published “pro-bias” data stem from datasets with substantial variation in reported effect sizes and approaching a symmetric distribution. The effect size distribution in the EPC report dataset was restricted; most reported results were small and very few were negative.