# References

Assendelft WJ, Morton SC, Yu EI, et al. Spinal manipulative therapy for low back pain. A meta-analysis of effectiveness relative to other therapies. Ann Intern Med. Jun. 3. 2003;138(11):871-81. [pmid: 12779297].
Balk E, Tatsioni A, Lichtenstein A, et al. Effect of chromium supplementation on glucose metabolism and lipids: a systematic review of randomized controlled trials. Diabetes Care. Aug. 2007;30(8):2154-63. [pmid: 17519436].
Balk EM, Bonis PA, Moskowitz H, et al. Correlation of quality measures with estimates of treatment effect in meta-analyses of randomized controlled trials. JAMA. Jun. 12. 2002;287(22):2973-82. [pmid: 12052127].
Balk EM, Lichtenstein AH, Chung M, et al. Effects of omega-3 fatty acids on serum markers of cardiovascular disease risk: a systematic review. Atherosclerosis. Nov. 2006;189(1):19-30. [pmid: 16530201].
Berkey CS, Hoaglin DC, Mosteller F, et al. A random-effects regression model for meta-analysis. Stat Med. Feb. 28. 1995;14(4):395-411. [pmid: 7746979].
Bland JM, Altman DG. Multiple significance tests: the Bonferroni method. BMJ. Jan. 21. 1995;310(6973):170. [pmid: 7833759].
Chapell R, Reston J, Snyder D. Management of Treatment-Resistant Epilepsy, Evidence Report/Technology Assessment No. 77 (Prepared by ECRI Evidence-based Practice Center under Contract No 290-97-0020). Rockville, MD. Agency for Healthcare Research and Quality. May. 2003. AHRQ Publication No. 03-0028.
Colditz GA, Miller JN, Mosteller F. How study design affects outcomes in comparisons of therapy. I: Medical. Stat Med. Apr. 1989;8(4):441-54. [pmid: 2727468].
Coulter I, Hardy M, Shekelle P, et al. Effect of the Supplemental Use of Antioxidants Vitamin C, Vitamin E, and Coenzyme Q10 for the Prevention and Treatment of Cancer, Evidence Report/Technology Assessment No. 75 (Prepared by Southern California Evidence-based Practice Center under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. August. 2003. AHRQ Publication No. 03-E047.
Counsell C, Sandercock P. Use of anticoagulants in patients with acute ischemic stroke. Stroke. Mar. 1995;26(3):522-3. [pmid: 7533952].
Donahue K, Gartlehner G, Jonas D, et al. Comparative Effectiveness of Drug Therapy for Rheumatoid Arthritis and Psoriatic Arthritis in Adults, Comparative Effectiveness Review No. 11 (Prepared by RTI-University of North Carolina Evidence-based Practice Center under Contract No. 290-02-0016). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. AHRQ Publication No. 08-EHC004-EF.
Egger M, Juni P, Bartlett C, Holenstein F, Sterne J. How important are comprehensive literature searches and the assessment of trial quality in systematic reviews? Empirical study. Health Technol Assess. 2003;7(1):1-76.
Emerson JD, Burdick E, Hoaglin DC, et al. An empirical study of the possible relation of treatment differences to quality scores in controlled randomized clinical trials. Control Clin Trials. Oct. 1990;11(5):339-52. [pmid: 1963128].
Furlan AD, Imamura M, Dryden T, Irvin E. Massage for low-back pain. Cochrane Database Syst Rev. 2008;(4). CD001929.
Furlan AD, van Tulder M, Cherkin D, et al. Acupuncture and dry-needling for low back pain: an updated systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). Apr. 15. 2005;30(8):944-63. [pmid: 15834340].
Hagen KB, Hilde G, Jamtvedt G, et al. Bed rest for acute low back pain and sciatica. Nurs Times. Aug. 2–8. 2001;97(31):40.
Hansen RA, Gartlehner G, Webb AP, et al. Efficacy and safety of donepezil, galantamine, and rivastigmine for the treatment of Alzheimer's disease: a systematic review and meta-analysis. Clin Interv Aging. 2008;3(2):211-25. [pmid: 18686744].
Hardy M, Coulter I, Morton SC, et al. S-Adenosyl-L-Methionine for Treatment of Depression, Osteoarthritis, and Liver Disease, Evidence Report/Technology Assessment No. 64 (Prepared by the Southern California Evidence-based Practice Center under Contract No. 290-97-0001). Rockville, MD. Agency for Healthcare Research and Quality. October. 2002. AHRQ Publication No. 02-E034.
Harford TC, Muthen BO. The dimensionality of alcohol abuse and dependence: a multivariate analysis of DSM-IV symptom items in the National Longitudinal Survey of Youth. J Stud Alcohol. Mar. 2001;62(2):150-7. [pmid: 11327181].
Hartling L, Ospina M, Liang Y, et al. Risk of bias versus quality assessment of randomised controlled trials: cross sectional study. BMJ. 2009;339:b4012. [pmid: 19841007].
Hayden JA, van Tulder MW, Malmivaara A, Koes BW. Exercise therapy for treatment of non-specific low back pain. Cochrane Database Syst Rev. 2005;(3). CD000335.
Henschke N, Ostelo RW, van Tulder MW, et al. Behavioural treatment for chronic low-back pain. Cochrane Database Syst Rev. 2010;(7). CD002014.
Heymans MW, van Tulder MW, Esmail R, et al. Back schools for nonspecific low back pain: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). Oct. 1. 2005;30(19):2153-63. [pmid: 16205340].
Higgins J, Green S. Cochrane handbook for systematic reviews of interventions version 5.0.2. updated September 2009. Cochrane Collaboration. 2008.
Hughes E, Collins J, V P. Bromocriptine for unexplained subfertility in women. Cochrane Database Syst Rev. 1996;4.
Jadad AR, Moore RA, Carroll D, et al. Assessing the quality of reports of randomized clinical trials: is blinding necessary?. Control Clin Trials. Feb. 1996;17(1):1-12. [pmid: 8721797].
Juni P, Altman DG, Egger M. Systematic reviews in health care: Assessing the quality of controlled clinical trials. BMJ. Jul. 7. 2001;323(7303):42-6. [pmid: 11440947].
Juni P, Tallon D, Egger M. Garbage in - garbage out? Assessment of the quality of controlled trials in meta-analyses published in leading journals. Proceedings of the 3rd symposium on systematic reviews: beyond the basics. St Catherine's College, Oxford Oxford. Centre for Statistics in Medicine. 2000:19.
Juni P, Witschi A, Bloch R, et al. The hazards of scoring the quality of clinical trials for meta-analysis. JAMA. Sep. 15. 1999;282(11):1054-60. [pmid: 10493204].
Kane RL, Wang J, Garrard J. Reporting in randomized clinical trials improved after adoption of the CONSORT statement. J Clin Epidemiol. Mar. 2007;60(3):241-9. [pmid: 17292017].
Karjalainen K, Malmivaara A, van Tulder M, et al. Multidisciplinary biopsychosocial rehabilitation for subacute low back pain in working-age adults: a systematic review within the framework of the Cochrane Collaboration Back Review Group. Spine (Phila Pa 1976). Feb. 1. 2001;26(3):262-9. [pmid: 11224862].
Khadilkar A, Milne S, Brosseau L, et al. Transcutaneous electrical nerve stimulation (TENS) for chronic low-back pain. Cochrane Database Syst Rev. 2005;(3). CD003008.
Kirkham JJ, Dwan KM, Altman DG, et al. The impact of outcome reporting bias in randomised controlled trials on a cohort of systematic reviews. BMJ. 2010;340:c365. [pmid: 20156912].
Kjaergard LL, Villumsen J, Gluud C. Quality of randomised clinical trials affects estimates of intervention efficacy. Proceedings of the 7th Cochrane colloquium. Universita STommaso D'Aquino, Rome Milan. Centro Cochrane Italiano. 1999:57. poster B10.
Kjaergard LL, Villumsen J, Gluud C. Reported methodologic quality and discrepancies between large and small randomized trials in meta-analyses. Ann Intern Med. Dec. 4. 2001;135(11):982-9. [pmid: 11730399].
Lensing AW, Prins MH, Davidson BL, et al. Treatment of deep venous thrombosis with low-molecular-weight heparins. A meta-analysis. Arch Intern Med. Mar. 27. 1995;155(6):601-7. [pmid: 7887755].
Lo GH, LaValley M, McAlindon T, et al. Intra-articular hyaluronic acid in treatment of knee osteoarthritis: a meta-analysis. JAMA. Dec. 17. 2003;290(23):3115-21. [pmid: 14679274].
Loonen AJ, Peer PG, Zwanikken GJ. Continuation and maintenance therapy with antidepressive agents. Meta-analysis of research. Pharm Weekbl Sci. Aug. 23. 1991;13(4):167-75. [pmid: 1834986].
Loosemore TM, Chalmers TC, Dormandy JA. A meta-analysis of randomized placebo control trials in Fontaine stages III and IV peripheral occlusive arterial disease. Int Angiol. Jun. 1994;13(2):133-42. [pmid: 7525794].
Mari JJ, Streiner DL. An overview of family interventions and relapse on schizophrenia: meta-analysis of research findings. Psychol Med. Aug. 1994;24(3):565-78. [pmid: 7991739].
Marshall JK, Irvine EJ. Rectal aminosalicylate therapy for distal ulcerative colitis: a meta-analysis. Aliment Pharmacol Ther. Jun. 1995;9(3):293-300. [pmid: 7654892].
Moher D, Pham B, Jones A, et al. Does quality of reports of randomised trials affect estimates of intervention efficacy reported in meta-analyses?. Lancet. Aug. 22. 1998;352(9128):609-13. [pmid: 9746022].
Moja LP, Telaro E, D'Amico R, et al. Assessment of methodological quality of primary studies by systematic reviews: results of the metaquality cross sectional study. BMJ. May. 7. 2005;330(7499):1053. [pmid: 15817526].
Pace F, Maconi G, Molteni P, et al. Meta-analysis of the effect of placebo on the outcome of medically treated reflux esophagitis. Scand J Gastroenterol. Feb. 1995;30(2):101-5. [pmid: 7732329].
Pildal J, Hrobjartsson A, Jorgensen KJ. Impact of allocation concealment on conclusions drawn from meta-analyses of randomized trials. Int J Epidemiol. Aug. 2007;36(4):847-57. [pmid: 17517809].
Ramirez-Lassepas M, Cipolle RJ. Medical treatment of transient ischemic attacks: does it influence mortality?. Stroke. Mar. 1988;19(3):397-400. [pmid: 3354028].
Roelofs PD, Deyo RA, Koes BW. Nonsteroidal anti-inflammatory drugs for low back pain: an updated Cochrane review. Spine (Phila Pa 1976). Jul. 15. 2008;33(16):1766-74. [pmid: 18580547].
Schulz KF, Chalmers I, Hayes RJ, et al. Empirical evidence of bias. Dimensions of methodological quality associated with estimates of treatment effects in controlled trials. JAMA. Feb. 1. 1995;273(5):408-12. [pmid: 7823387].
Shekelle P, Hardy ML, Coulter I, et al. Effect of the supplemental use of antioxidants vitamin C, vitamin E, and coenzyme Q10 for the prevention and treatment of cancer. Evid Rep Technol Assess (Summ). Oct. 2003;(75):1-3.
Shekelle PG, Maglione M, Bagley S, et al. Efficacy and Comparative Effectiveness of Off-Label Use of Atypical Antipsychotics, Comparative Effectiveness Review No. 6 (Prepared by the Southern California/RAND Evidence-based Practice Center under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. January. 2007. AHRQ Publication No.07-EHC003-EF.
Shekelle PG, Morton SC, Maglione M, et al. Pharmacological and Surgical Treatment of Obesity, Evid Report/Technology Assessment No. 103 (Prepared by the Southern California/RAND Evidence-based Practice Center under Contract No. 290-02-0003). Rockville, MD. Agency for Healthcare Research and Quality. July. 2004. AHRQ Publication No. 04-E028-2.
Sutherland LR, May GR, Shaffer EA. Sulfasalazine revisited: a meta-analysis of 5-aminosalicylic acid in the treatment of ulcerative colitis. Ann Intern Med. Apr. 1. 1993;118(7):540-9. [pmid: 8095128].
Towfigh A, Romanova M, Weinreb JE, et al. Self-monitoring of blood glucose levels in patients with type 2 diabetes mellitus not taking insulin: a meta-analysis. Am J Manag Care. Jul. 2008;14(7):468-75. [pmid: 18611098].
Urban R, Demetrovics Z. Smoking outcome expectancies: A multiple indicator and multiple cause (MIMIC) model. Addict Behav. Jun. 2010;35(6):632-5. [pmid: 20167433].
Van Duijvenbode IC, Jellema P, van Poppel MN, et al. Lumbar supports for prevention and treatment of low back pain. Cochrane Database Syst Rev. 2008;(2). CD001823.
Van Tulder M, Furlan A, Bombardier C, et al. Updated method guidelines for systematic reviews in the cochrane collaboration back review group. Spine (Phila Pa 1976). Jun. 15. 2003;28(12):1290-9. [pmid: 12811274].
Van Tulder MW, Suttorp M, Morton S, et al. Empirical evidence of an association between internal validity and effect size in randomized controlled trials of low-back pain. Spine (Phila Pa 1976). Jul. 15. 2009;34(16):1685-92. [pmid: 19770609].
Van Tulder MW, Touray T, Furlan AD, et al. Muscle relaxants for nonspecific low back pain: a systematic review within the framework of the cochrane collaboration. Spine (Phila Pa 1976). Sep. 1. 2003;28(17):1978-92. [pmid: 12973146].
Verhagen AP, de Vet HC, de Bie RA, et al. The Delphi list: a criteria list for quality assessment of randomized clinical trials for conducting systematic reviews developed by Delphi consensus. J Clin Epidemiol. Dec. 1998;51(12):1235-41. [pmid: 10086815].
Welton N, Ades A, Carlin J, et al. Models for potentially biased evidence in meta-analysis using empirically based priors. Journal of the Royal Statistical Society: Series A (Statistics in Society). 2009;172:119-36.
West S, King V, Carey TS, et al. Systems to rate the strength of scientific evidence. Evid Rep Technol Assess (Summ). Mar. 2002;(47):1-11.
Wood L, Egger M, Gluud LL, et al. Empirical evidence of bias in treatment effect estimates in controlled trials with different interventions and outcomes: meta-epidemiological study. BMJ. Mar. 15. 2008;336(7644):601-5. [pmid: 18316340].