# Discussion

This report quantifies the risk of bias associated with selected quality criteria across three different datasets. Our analyses show that the association between quality features and effect sizes is complex and may vary according to factors yet to be explored.

## Quality of the Reporting

We found in all datasets that the quality of the reporting was lacking. Many studies in our datasets reported insufficient information to know whether a quality feature was met or not. Poor reporting in publications does not necessarily mean poor study quality. The majority of our analyses compared studies reporting positive features with studies where the quality feature was not reported, such as concealed treatment allocation. Hence, we were primarily concerned with demonstrating the effects of high-quality studies that reported a feature, and the expression of the feature was an indicator of high quality. Here, quality included the reporting, as well as quality in the design, conduct, and analysis of the study. Similarly, a recent study by Hartling, Ospina, Liang, et al. (2009) applying the Cochrane risk of bias (2008 version) compared studies with a high risk of bias with studies of low quality or unclear quality. We could also show in the analyzed datasets that the reporting has improved since publication of the Consort statement, in accordance with the observation of other reviewers (Kane, Wang, and Garrard, 2007).

However, it has to be considered that all included randomized controlled trials within datasets were identified through meta-analyses. The trials were all considered adequate for inclusion in a published meta-analysis. Moja et al. (2005) showed that 12 percent of Cochrane and the Database of Abstracts of Reviews of Effects (DARE) selected reviews used quality as an inclusion criterion. For Evidence-based Practice Center (EPC) reports in particular, this approach is also not uncommon, especially when sufficient high-quality studies are available. The quality of randomly selected trials may be lower still than encountered in our selected datasets.

## Psychometric Analysis

First, our psychometric analysis indicates that the quality criterion “similar timing of outcome assessment” should be reassessed for inclusion in the 11-item list. This criterion is usually met; only 2 to 11 percent of studies across datasets indicate the possibility or evidence of differential outcome assessment.

Furthermore, we explored the interrelationship between quality features psychometrically and through the use of a multiple indicator multiple cause (MIMIC) model factor analysis. We were able to show that across all three datasets, several individual quality features showed substantial intercorrelations but the complete set of 11 items did not show marked internal consistency.

Although conceptually presumably independent, in practice we find that studies that observe good practice for selected quality features often also do so for other features. Studies that reported an adequate method of randomization sequence generation tended to also report the use of adequate treatment allocation concealment (intercorrelations ranging from 0.49 to 0.74 across datasets). Furthermore, the Cochrane Back Review Group (CBRG) criteria list differentiates patient, provider, and assessor blinding, but our analyses did not provide support for this differentiation. In our empirical data samples these features are substantially intercorrelated, and in particular the provider blinding does not appear to contribute unique information. In two of the datasets, one of the three blinding items had to be excluded from the factor analyses due to collinearity. Therefore, while appealing conceptually, the distinction between blinding the patient, provider, or outcome assessor may not all independently assess study quality.

However, when treating the items as the indicator of the same underlying construct, we found insufficient internal consistency to indicate a homogenous quality construct. The Cronbach's alpha values in all three datasets were below values expected for a psychometric scale (alphas ranging from 0.55 to 0.61).

A factor analysis taking into account the intercorrelations between items as well as their effect on the reported treatment effect did not favor a one-factor solution. Best fit was achieved through three factors in all three datasets. The factors were similar, but the factorial validity was not perfect either, with some items loading on different factors across datasets. The randomization sequence and the allocation concealment item consistently formed a factor, and the blinding items also consistently formed a second factor across datasets. The other items were not represented by these factors, indicating an additional source of variance. A third factor consistently showed significant loading for acceptable dropout rates. Other items such as original group (intention to treat [ITT]) did also load on this factor but with less consistency across datasets.

The use of checklists when scoring quality versus the application of a summary score has been extensively discussed in the literature. Juni and colleagues (Juni, Witschi, Bloch, et al., 1999; Juni, Douglas, Altman, et al., 2001) raised serious concerns about the use of quantitative sum scores. However, treating all quality items as completely independent does also not appear appropriate either following our analyses. The Cochrane review handbook currently suggests the use of a domain-based evaluation of quality in which critical assessments are made separately for different domains (Higgins and Green, 2009). The equal weighing of each item as applied in our approach is common place but not validated. Depending on the intervention and the clinical field, some internal validity threats may be more pertinent than others; however there are as yet no data to guide what these associations may be. Quality criteria could be used to trigger an overall assessment of quality which is more qualitatively derived than quantitatively by adding individual item scores. The reliability of qualitative overall evaluations have to be considered though, as Hartling et al. (2009) reported a kappa of 0.27 for reviewers to agree on the Cochrane Overall Risk of Bias dimension (Higgins and Green, 2008). A combined qualitative and quantitative approach may be useful: quality features could be ranked by importance for the clinical field a priori and weighted accordingly for a summary score.

Validating scales used to assess the quality of trials is very difficult. The concept of quality is not easy to define and there is no widely accepted gold standard. In one of the datasets we applied the Jadad items and scale and the criteria suggested by Schulz et al. (1995) parallel to our proposed criteria following the original scoring guidelines. We were able to show convergent validity across quality domains. The correlations with the Jadad and the Schulz scales were satisfying throughout and ranged between 0.63 and .0.93. However, the crucial validity test for quality items is the predictive validity of the quality features and possibly scales—is there evidence of bias, and is meeting or not meeting the quality criteria associated with differential effect sizes.

## Associations Between Internal Validity and Effect Sizes

This report provides empirical data on the impact of fulfilling or not fulfilling the quality criteria sequence of randomization, concealment of treatment allocation, similarity of baseline values, assessor blinding, care provider blinding, patient blinding, dropout rate, ITT analysis, similarity of cointerventions, acceptable compliance, and similar timing of outcome assessment across three datasets. Although the majority of systematic reviews assess the quality of included studies, and meta-regression analyses trying to trace the effects of quality are often undertaken, there are relatively few published studies showing an effect of quality on effect sizes, that is, empirical evidence of bias in reported study results that can presumably be attributed to the quality of the reporting or the conduct of the research study. For many suggested quality criteria and potential threats to the internal validity of RCTs (see e.g.,West et al., 2002; Moja et al., 2005) there is still a dearth of published evidence on the extent of bias, that is, does not meeting the quality criteria show associations with the observed treatment effect.

The 11 proposed quality features contribute information to the evaluation of back pain trials as previously reported (Van Tulder et al., 2009). Although not statistically significant, individual features showed consistently associations with effect sizes depending on the quality of the trial. High-quality studies reported smaller effect sizes, indicating that low-quality studies tended to overestimate treatment effects. A dataset consisting of trials included in EPC reports showed a different pattern. The EPC dataset analysis showed for the majority of individual quality dimensions that the high quality studies in the dataset tended to reported larger treatment effects than the low quality trials that did not meet the quality criterion. The third dataset showed the most variation across quality criteria, but was more similar to the back pain dataset, in that meeting most individual criteria where associated with smaller effect sizes.

The feature allocation concealment showed the most consistent results across datasets. In all three datasets, allocation concealment was associated with effect sizes, and the direction of effect did not vary. Unconcealed trials reported smaller effect sizes in the back pain dataset (effect size difference -0.08, 95% CI: -0.23, 0.07) and the EPC report dataset (effect size difference -0.06, 95% CI: -0.22, 0.11), and the ratio of odds ratios (ROR) in the third dataset also showed that unconcealed trials reported larger treatment effects (ROR=0.91, 95% CI: 0.72, 1.14). This analysis indicated that unconcealed trials tend to overestimate the treatment effect. Similarly, Pidal et al. (2007) reported an ROR of 0.90 (0.81, 1.01); Wood et al. (2008) found a ROR of 0.91 (95% CI 0.80, 1.03) for objective and 0.69 (95% CI: 0.59, 0.82) for subjective outcomes. A pooled analysis using data from Schulz et al. (1995), Moher et al. (1998), Kjaergard et al. (2000), and Juni et al. (2000) showed an ROR of 0.70 (95% CI: 0.62, 0.80) across datasets (Juni et al., 2001). The influence of concealment of allocation on effect size seems to be the most consistent quality criteria.

When applying a total sum score derived from the mean item scores and regressing effect sizes on the sum score, we found no statistically significant linear effect. A simple linear relationship indicates that the reported treatment effects increase the lower the quality level. A similar approach was described by Emerson et al. (1990), who also found no linear relation between quality score and variation in treatment differences.

When using factor scores, rather than individual quality features or a simple sum score, we also did not find that these quality factors predicted effect sizes. The factor structure takes the inter-item correlations as well as their individual association with effect sizes into account. MIMIC models are generally a promising approach to describe complex relations between multiple predictors and has been applied in a variety of fields (e.g.,Hartford & Muthén, 2001; Urban & Demetrovics, 2010).

One power maximizing approach showed consistently statistically significant effects. Cutoff values based on the number of fulfilled quality criteria were able to differentiate high- and low-quality studies. In all three datasets, 5 or 6 (out of 11) fulfilled quality criteria differentiated the studies best. In dataset 1 (back pain) and dataset 3 (“pro-bias”), the replication of the set used by Moher et al. (1998) high-quality studies showed smaller treatment effects. Effect size differences were -0.20 in dataset #1 and the RORs were 0.79 (cutoff at 5) and 0.77 (cutoff at 6) in the third dataset when taking several quality criteria into account. However, in the EPC report dataset, we found unexpected results: studies with five or six fulfilled quality feature reported larger effect sizes than the low-quality trials (effect size difference 0.27). Moher et al. (1998) used the Jadad scale, which takes three individual quality features into account (randomization, blinding, withdrawals) to differentiate high- and low-quality studies, and reported a ratio of odds ratio of 0.66 (95% CI: 0.52, 0.83). Our results are similar in direction for two of the three datasets, but we found less-pronounced results. The difference in results may be due to the selected statistical approach and presumably in part due to the nonperfect overlap of studies since we were unable to obtain a quarter of the original dataset.

Comparing results across methods to test associations between quality criteria and effect sizes, the differences between the originally analyzed back pain dataset and the EPC report dataset are most striking. The quality criteria were developed for the CBRG and they also appear to be most useful in this dataset (see also van Tulder et al., 2003). However, it is possible that the tendency of EPC reports to consider quality as an inclusion criterion, potentially excluding fatally flawed studies from the review, is partly responsible for the different results in this dataset. The quality scores indicated that for several criteria such as blinding, similarity of cointerventions, and ITT analysis, the trials included in EPC reports scored higher.

## Moderators and Confounders

The identified associations between quality and effect sizes varied across our datasets presented in this report which reflects also the extent of conflicting results reported in the literature (e.g., Moher et al., 1998, Balk et al., 2002; Juni et al., 2001). Research on the association between quality and effect sizes should focus on factors that can help predict when lack of quality is likely to result in a distorted estimate of treatment effects.

In this report, we investigated a number of differences across datasets. The systematically investigated moderators and confounders were the size of the treatment effect within meta-analyses, the condition being treated, the type of outcome, and the variance in effect sizes. These moderators did not sufficiently explain diverging results across our employed datasets.

The condition being treated or the clinical field the study was conducted in was not sufficient to explain differential effects of the association between quality and effect sizes. The size of the treatment effect could also not be shown as a significant moderator between the two variables. Unlike Wood et al. (2009), we could not show that the type of outcome explained differences in effects of associations; there was no statistically significant difference between slopes. However, it has to be noted that the type of outcome is to some extent already been taking into account in the CBRG guidance: assessor blinding is assumed for studies with automated test result analysis, it is assumed that the assessor is clearly not aware of the treatment allocation, regardless of whether the publication states that the assessor was blind.

The variance in effect sizes across a dataset was one factor that should be explored further in future research to see if this factor contributes to the question of when quality features are likely to influence effect sizes. Balk et al. (2002) used existing heterogeneity in odds ratios as an inclusion criterion for their meta-epidemiological study but concluded that the investigated quality measure are not reliable associated with the strength of treatment effect. Whether the variance in effect sizes is indeed a sufficient moderator to explain variation across datasets is a testable question and could be assessed with Monte Carlo simulations systematically investigating the effect of moderators or confounders that influence the association between quality and effect sizes.

## Implication for Practice

In two of these last datasets, we showed that quality features can affect reported treatment effects. The 11 proposed quality features developed for the CBRG contribute information to the evaluation of back pain trials as previously reported (Van Tulder et al., 2009). Whether this extended list of quality features can be proposed for a more general use was one of the principal questions of this research project. Their general applicability has not been supported, as their effect was not uniform across datasets.

We conclude from our analyses that the association between quality features and reported treatment effects should be explored in systematic reviews. Regardless of whether quality criteria are assessed individually, through empirically derived factor scores or the use of a total score, regardless of whether the summary score was quantitatively, quantitative or through a combination derived, and regardless of whether low quality studies are excluded from the analysis or studies are pooled weighted by quality (e.g. Juni, Altman, and Egger, 2001; Welton, Ades, Altman, et al., 2009) quality should be taken into account when evaluating the existing evidence and the potential bias should be quantified. For situations where the Jadad criteria may be insufficiently applicable, our data provide some support for the use of the II-item CBRG list.

## Future Research

Applying psychometric principles to the field of quality criteria is rarely explored but can provide useful insight into empirical associations of quality items. In this report we explored the reliability of the proposed quality items only through item and scale analysis. Future work should include an analysis of agreement between raters. The reproducibility of quality judgments across independent raters is another valuable method for estimating the reliability of proposed items or scales. Previous research has shown that also carefully developed tools may show disappointing rater agreement when scoring agreement is tested. Hartling et al. (2009) reported kappas ranging from 0.13 to 0.74 for domains of the Cochrane Risk of Bias tool. For evidence reviews, however, we suggest an additional approach for testing the reliability of tools. In systematic reviews, it is now standard to employ two independent raters when scoring the quality of included studies and to reconcile independent decisions for a final score. This approach helps to avoid individual reviewer bias and errors and the reconciled decision should be more reliable than the individual decision. The rater agreement of reconciled decisions across pairs of raters is a better indicator of the reliability of the tool because it mirrors more closely how the tool will be used in practice.

There is a need for more information on individual quality features and empirical evidence of bias. This concerns the many suggested quality criteria for which no empirical evidence is available yet or at least no summary across individual meta-analyses exists (see West et al., 2002; Moja et al., 2005). There are other quality criteria such as selective outcome reporting (Kirkham, Dwan, Altman, et al., 2010) that may be difficult to operationalize and a replication of the effect in a different dataset would be useful. The scarcity of evidence is disappointing considering the fact that quality scoring is a standard method in systematic reviews. Many different quality criteria are used by reviewers and many represent possible and plausible threats to the validity of the study. Future reviews should report data on these associations in order to advance the evidence base for quality assessments.

The association between quality features and effect sizes is complex, and the conditions, when lack of quality is most likely to lead to bias, should be explored further in future research. Factors such as the variance in quality scores and effect sizes across studies could be systematically studied in “virtual datasets,”, that is, by creating datasets employing Monte Carlo simulation methods. Using datasets of “known” properties would be useful to further study associations between the proposed quality criteria and effect sizes. An increase in sample size and thereby statistical power would enable researchers to detect small but systematic effects and shed further light on the question of when quality features are most useful to be taken into account when assessing treatment effects in published research.

## Conclusions

The associations between quality features and effect sizes are complex. Effect sizes of individual studies depend on many factors. In two datasets, individual quality items and summary scores of items were associated with differences in effect sizes. This relationship was not found in the remaining dataset. Despite several exploratory analyses, we were not able to explain these differences. The conditions under which quality features and which features lead to biased effect sizes warrant further exploration, and factors such as the variance in quality scores and effect sizes will be investigated in a subsequent project.