# Background

Trial design and execution factors are widely believed to be associated with bias in randomized controlled trials (RCT). Bias is typically defined as a systematic deviation of an estimate, such as the estimated treatment effect from the true value. A number of individual quality criteria and quality checklists or scales for RCTs have been proposed (see e.g., Moja, Telaro D'Amico, et al. 2005; West, King, Carey, et al., 2002). These cover potential threats to the internal validity of the trial methodology.

Quality checklists typically provide a selection of quality features that are scored individually. Quality scales provide in addition a total quality score, either by summing up individual features giving equal weights to each feature or by putting more emphasis on selected features. Existing quality checklists and scales address the conduct or research methodology of the individual study, so they concern the internal validity of the research study, but they frequently also include other quality aspects of publications. Jadad and colleagues (Jadad, Moore, Carroll, et al., 1996) proposed a scale of 0 to 5 to evaluate RCTs with “low” and “high” internal validity in pain research. The Jadad scale, based on three criteria (randomization, double-blinding, and a description of dropouts), is widely used as a summary quality measure of randomized controlled trials (RCTs) and is one of the few tools where the psychometric properties have been evaluated and are acceptable. However, the Jadad scale has some limitations, e.g., the double blinding criterion is usually reported in fewer than 10 to 20 percent of studies. Many trials involve devices, surgery, or other interventions for which double blinding is either impractical or impossible and the double blinding criterion accounts for 40 percent of the Jadad score. An additional criterion, the concealment of treatment allocation, is not included in the Jadad scale but is widely used in addition to the criteria proposed by Jadad et al. (1996). Verhagen, de Vet, de Bie, et al. (1998) developed a nine-item list of quality items specifically focused on internal validity, using a formal Delphi process of three rounds, which included leading experts from around the world. The 2008 Cochrane handbook (Higgins and Green, 2008) introduced a Risk of Bias tool based on the domains sequence generation, allocation concealment, blinding, incomplete outcome data, selective outcome reporting, and other sources of bias.

More factors have been proposed as related to bias than have actually been confirmed by systematic examination. Only a few researchers have published investigations of the association between selected trial quality and effect sizes obtained in individual trials. It is assumed that the conduct of the research methodology will influence the result that is obtained by the trial. The study methodology appears to distort the true value expected to be shown in the study. Typically, it is assumed that low-quality trials exaggerate treatment effects. Colditz, Miller, and Mosteller (1989) found RCTs to have smaller effect sizes than non-RCTs in studies of surgical therapy and RCTs that are double blind have smaller effect sizes than nonblinded trials of medical therapy. Schulz, Chalmers, Hayes, et al. (1995) assessed 250 trials in 33 meta-analyses and reported that inadequate concealment of allocation accounted for a 41 percent increase in effect sizes. The lack of double blinding showed a 17 percent increase in reported treatment effect. Contrarily, Emerson, Burdick, Hoaglin, et al. (1990) found no relationship between a consensus-developed quality scale (0–100 points) and treatment differences. Balk and colleagues (Balk, Bonis, Moskowitz, et al., 2002) applied 24 existing quality measures and assessed 26 meta-analyses involving 276 RCTs. The analysis focused on four conditions: cardiovascular disease, infectious disease, pediatrics, and surgery. The study found no indication of bias; individual quality measures were not reliably associated with the strength of treatment effect across studies and clinical areas. Moher, Pham, Jones, et al. (1998) used Jadad's scale and Schulz's “concealment of allocation” in a large study assessing 11 meta-analyses including 127 RCTs. All trials were scored and the meta-analyses replicated. Low-quality studies were associated with an increased treatment estimate of 34 percent compared with high-quality trials. Studies with inadequate treatment allocation concealment showed a 37 percent increased effect compared to concealed trials. Juni, Altman, and Egger (2001) have summarized the data from Schulz et al. (1995), Moher et al. (1998), Kjaergard, Villumsen, and Gluud (1999) and Juni, Tallon, Egger, et al. (2000) in a pooled analysis and provide evidence for associations of effect sizes with allocation concealment (ratio of odds ratios [ROR] 0.70; 95% CI: 0.62, 0.80) and double blinding (ROR 0.86; 95% CI: 0.74, 0.99) while the generation of treatment allocation did not have a statistically significant effect across datasets (ROR 0.81; 95% CI: 0.60, 1.09). Pidal, Hrobjartsson, Jorgensen, et al. (2007) outline the potential consequences for meta-analysis conclusions. When only trials with adequate concealment were included in meta-analyses, two-thirds lost statistical significance of the primary result, primarily to loss of power (as a result of a smaller sample size) but also a shift in the point estimate towards a less beneficial effect. These studies provide data on quantifying the risk of bias associated with individual or sets of quality criteria.

The association between quality features and effect sizes may vary across datasets according to factors yet to be explored. Investigating moderators and confounders that may influence the association between quality and effect sizes and that may explain some of the conflicting results shown in the literature is an evolving field. Wood, Egger, Gluud, et al. (2009) used three sets of “meta-epidemiological studies,” that is, studies investigating the associations of quality features and effect sizes (Kjaergard, Villumsen & Gluud, 2001; Schulz, et al., 1995; Egger, Juni, Bartlett, Holenstein, and Sterne, 2003). The group investigated whether the nature of the intervention and the type of outcome measures influences the effect of allocation concealment and blinding. They found that studies using subjective outcomes showed exaggerated effect sizes when there was inadequate or unclear allocation concealment or lack of blinding. In studies using objective outcomes such as mortality, the association of quality with trial results was negligible. Differentiating drug interventions and nondrug interventions showed no significant differences on the effect on allocation concealment or blinding.

Recently, quality criteria suggested by the Cochrane Back Review Group (CBRG) were found to be associated with effects sizes in RCTs of interventions for back pain (van Tulder, Suttorp, Morton, et al., 2009). The CBRG Editorial Board developed an 11-item criteria list, based on the 9-item Delphi list (Verhagen et al., 1998) and the 3-item Jadad criteria, for evaluation of internal validity of RCTs (van Tulder, Furlan, Bombardier, et al., 2003). Modifications were made to tailor the criteria list to the expected needs of trials of treatments for back pain. The Delphi list was modified by adding three items that had been eliminated between rounds two and three of the Delphi (items about withdrawals and dropouts, compliance rate, and co-interventions), deleting one Delphi list criterion on specifying eligibility criteria and adding one item about the timing of measurement of outcomes. This 11-item list was then proposed by the CBRG editorial board as the standard measure for assessing quality of controlled trials and has been used in virtually all CBRG reviews. A summary score of 0 to 11, based on the 11-item list, was developed as a measure of overall internal validity. Results of applying this set of criteria on all trials of nonsurgical therapy in CBRG reviews showed consistent effects of the criteria on effect sizes.

We aim to assess the potential usefulness of the set of CBRG quality criteria to other clinical conditions by applying these criteria to large datasets of RCTs covering diverse clinical topics and diverse outcome measures. We examine the empirical evidence of associations between individual quality criteria as well as summary scores. In addition, factors influencing the association between quality and effect sizes are explored.