# Quality Rating Form

## Cochrane Back Review Group

Cochrane Back Review Group Quality Items

### Scoring Guidelines Cochrane Back Review Group

#### Randomization sequence

A random (unpredictable) assignment sequence. Examples of adequate methods are coin toss (for studies with two groups), rolling a dice (for studies with two or more groups), drawing of balls of different colours, drawing of ballots with the study group labels from a dark bag, computergenerated random sequence, pre-ordered sealed envelops, sequentially-ordered vials, telephone call to a central office, and pre-ordered list of treatment assignments Examples of inadequate methods are: alternation, birth date, social insurance/security number, date in which they are invited to participate in the study, and hospital registration number

#### Allocation concealment

Assignment generated by an independent person not responsible for determining the eligibility of the patients. This person has no information about the persons included in the trial and has no influence on the assignment sequence or on the decision about eligibility of the patient.

#### Patient blinding

This item should be scored “yes” if the index and control groups are indistinguishable for the patients or if the success of blinding was tested among the patients and it was successful.

#### Care provider blinding

This item should be scored “yes” if the index and control groups are indistinguishable for the care providers or if the success of blinding was tested among the care providers and it was successful

#### Assessor blinding

Adequacy of blinding should be assessed for the primary outcomes. This item should be scored “yes” if the success of blinding was tested among the outcome assessors and it was successful or:

- for patient-reported outcomes in which the patient is the outcome assessor (e.g., pain, disability): the blinding procedure is adequate for outcome assessors if participant blinding is scored “yes”
- for outcome criteria assessed during scheduled visit and that supposes a contact between participants and outcome assessors (e.g., clinical examination): the blinding procedure is adequate if patients are blinded, and the treatment or adverse effects of the treatment cannot be noticed during clinical examination
- for outcome criteria that do not suppose a contact with participants (e.g., radiography, magnetic resonance imaging): the blinding procedure is adequate if the treatment or adverse effects of the treatment cannot be noticed when assessing the main outcome
- for outcome criteria that are clinical or therapeutic events that will be determined by the interaction between patients and care providers (e.g., co-interventions, hospitalization length, treatment failure), in which the care provider is the outcome assessor: the blinding procedure is adequate for outcome assessors if item “E” is scored “yes”
- for outcome criteria that are assessed from data of the medical forms: the blinding procedure is adequate if the treatment or adverse effects of the treatment cannot be noticed on the extracted data

#### Dropouts

The number of participants who were included in the study but did not complete the observation period or were not included in the analysis must be described and reasons given. If the percentage of withdrawals and dropouts does not exceed 20% for short-term follow-up and 30% for long-term followup and does not lead to substantial bias a ‘yes’ is scored. (N.B. these percentages are arbitrary, not supported by literature).

#### ITT

All randomized patients are reported/analyzed in the group they were allocated to by randomization for the most important moments of effect measurement (minus missing values) irrespective of noncompliance and co-interventions.

#### Baseline comparability

In order to receive a “yes”, groups have to be similar at baseline regarding demographic factors, duration and severity of complaints, percentage of patients with neurological symptoms, and value of main outcome measure(s).

#### Co-Interventions

This item should be scored “yes” if there were no co-interventions or they were similar between the index and control groups.

#### Compliance

The reviewer determines if the compliance with the interventions is acceptable, based on the reported intensity, duration, number and frequency of sessions for both the index intervention and control intervention(s). For example, physiotherapy treatment is usually administered over several sessions; therefore it is necessary to assess how many sessions each patient attended. For single-session interventions (for ex: surgery), this item is irrelevant.

#### Timing

Timing of outcome assessment should be identical for all intervention groups and for all important outcome assessments.

Note: These instructions are adapted from van Tulder 2003, Boutron et al, 2005 (CLEAR NPT) and the Cochrane Handbook of Reviews of Interventions2;5;9. 2008 Updated Guidelines for Systematic Reviews 9April 2008

## Jadad

Jadad Scale

Dimension | | | Sub Score
Randomization | 1. Was the study described as randomized (this includes the use of words such as randomly, random, and randomization)? = 1 point | Give 1 additional point if: For question 1, the method to generate the sequence of randomization was described and it was appropriate (table of random numbers, computer generated, etc.) Deduct 1 point if: For question 1, the method to generate the sequence of randomization was described and it was inappropriate (patients were allocated alternately, or according to date of birth, hospital number, etc.)
Blinding | 2. Was the study described as double blind? = 1 point | Give 1 additional point: If for question 2 the method of double blinding was described and it was appropriate (identical placebo, active placebo, dummy, etc.) Deduct 1 point: If for question 2 the study was described as double blind but the method of blinding was inappropriate (e.g., comparison of tablet vs. injection with no double dummy)
Withdrawals and dropouts | 3. Was there a description of withdrawals and dropouts? = 1 point
TOTAL JADAD SCORE

### Jadad Guidelines for Assessment

1. Randomization
  A method to generate the sequence of randomization will be regarded as appropriate if it allowed each study participant to have the same chance of receiving each intervention and the investigators could not predict which treatment was next. Methods of allocation using date of birth, date of admission, hospital numbers, or alternation should be not regarded as appropriate.
2. Double blinding
  A study must be regarded as double blind if the word “double blind” is used. The method will be regarded as appropriate if it is stated that neither the person doing the assessments nor the study participant could identify the intervention being assessed, or if in the absence of such a statement the use of active placebos, identical placebos, or dummies is mentioned.
3. Withdrawals and dropouts
  Participants who were included in the study but did not complete the observation period or who were not included in the analysis must be described. The number and the reasons for withdrawal in each group must be stated. If there were no withdrawals, it should be stated in the article. If there is no statement on withdrawals, this item must be given no points.

## Schulz's (1995) quality dimensions

(circle appropriate category)

1. Concealment of Treatment Allocation
  a. Adequately concealed trial (i.e. central randomization; numbered or coded bottles or containers; drugs prepared by the pharmacy; serially numbered; opaque, sealed envelopes; or other description that contained elements convincing of concealment
  b. Inadequately concealed trial (i.e. alternation or reference to case record numbers or dates of birth
  c. Unclearly concealed trial (authors did either not report an allocation concealment approach at all or reported an approach that did not fall into the categories above
2. Generation of Allocation Sequence
  a. Adequately sequence generation (random-number table, computer random-number generator, coin tossing, or shuffling)
  b. Publication does not report one of the adequate approaches, those with inadequate sequence generation
3. Inclusion in the Analysis of All Randomized Participants
  a. Publication reports or gives the impression that no exclusions have taken place (often not explicit)
  b. Publication reports exclusions (e.g., protocol deviation, withdrawals, dropouts, loss to follow-up)
4. Double Blinding
  a. Double-blinding reported
  b. Double-blinding not reported