# Comparison Random Effects Meta-regression Results

Table E1 Difference in odds ratios for proposed quality criteria (“pro-bias”), R

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | OR | 95% CI | OR | 95% CI | ROR | 95% CI
Randomization adequate | 34 | 66 | 0.44 | (0.31, 0.59) | 0.46 | (0.37, 0.59) | 1.05 | (0.69, 1.60)
Allocation concealment | 26 | 74 | 0.50 | (0.34, 0.75) | 0.44 | (0.35, 0.56) | 0.88 | (0.56, 1.39)
Similar baseline | 36 | 64 | 0.37 | (0.26, 0.52) | 0.51 | (0.40, 0.66) | 1.40 | (0.92, 2.12)
Assessor blind | 78 | 22 | 0.42 | (0.34, 0.52) | 0.65 | (0.42, 1.00) | 1.55 | (0.95, 2.51)
Care provider blind | 69 | 31 | 0.45 | (0.36, 0.58) | 0.46 | (0.32, 0.66) | 1.02 | (0.66, 1.57)
Patient blind | 72 | 28 | 0.44 | (0.35, 0.55) | 0.52 | (0.36, 0.76) | 1.20 | (0.77, 1.87)
Acceptable dropout rate | 62 | 38 | 0.50 | (0.38, 0.64) | 0.41 | (0.30, 0.55) | 0.83 | (0.57, 1.22)
Original group (ITT) | 29 | 71 | 0.46 | (0.32, 0.65) | 0.46 | (0.36, 0.58) | 1.00 | (0.65, 1.52)
Similar co-interventions | 68 | 32 | 0.40 | (0.32, 0.51) | 0.60 | (0.43, 0.84) | 1.51 | (1.00, 2.27)^*^
Acceptable compliance | 46 | 54 | 0.56 | (0.42, 0.75) | 0.39 | (0.30, 0.51) | 0.70 | (0.47, 1.03)
Similar timing | 89 | 11 | 0.44 | (0.36, 0.55) | 0.60 | (0.32, 1.11) | 1.35 | (0.71, 2.58)

* p<0.05

R = random effects meta-regression; OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios; ITT = intention to treat

Figure E1 Differences in effect sizes based on quality criteria (“pro-bias”), random effects meta-regression

CI = confidence interval; ITT = intention to treat

Figure E1 is a forest plot showing the differences in effect sizes between low and high quality studies for each quality feature in dataset 3 (‘pro-bias’) based on a random effects model. The direction of effects was not uniform across features (the low quality studies did not consistently report smaller odds ratios thereby overestimating the treatment effect); for several features there was no association between quality and effect sizes.

Table E2 Comparison of different quality cutoffs using a total score (“pro-bias”), R

Cut-off | Number Equal or Above Cut-off | Number Below Cut-off | High Quality | | Low Quality | | Difference
Cut-off | Number Equal or Above Cut-off | Number Below Cut-off | OR | 95% CI | OR | 95% CI | ROR | 95% CI
≥9 vs <9 | 14 | 86 | 0.39 | (0.23, 0.67) | 0.47 | (0.38, 0.58) | 1.20 | (0.68, 2.10)
≥8 vs <8 | 26 | 74 | 0.46 | (0.32, 0.67) | 0.46 | (0.36, 0.58) | 0.99 | (0.64, 1.55)
≥7 vs <7 | 44 | 56 | 0.39 | (0.29, 0.53) | 0.51 | (0.40, 0.67) | 1.31 | (0.88, 1.95)
≥6 vs <6 | 62 | 38 | 0.46 | (0.36, 0.59) | 0.46 | (0.32, 0.63) | 0.99 | (0.66, 1.49)
≥5 vs <5 | 76 | 24 | 0.45 | (0.36, 0.57) | 0.47 | (0.32, 0.71) | 1.05 | (0.66, 1.67)
≥4 vs <4 | 86 | 14 | 0.46 | (0.36, 0.55) | 0.53 | (0.32, 0.88) | 1.19 | (0.69, 2.06)

R = random effects meta-regression; OR = odds ratio; CI = confidence interval; ROR = ratio of odds ratios