# Comparison Fixed-Effects Model Results

Table D1 Difference in effect sizes (EPC reports), FE

Quality Feature | Number Criterion Met | Number Criterion Not Met | Effect Size in Trials With Criterion Met | | Effect Size in Trials With Criterion Not Met | | Effect Size Difference
Quality Feature | Number Criterion Met | Number Criterion Not Met | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
Randomization adequate | 44 | 121 | 0.59 | (0.56, 0.61) | 1.08 | (1.07, 1.10) | -0.50 | (-0.53, -0.47)^*^
Allocation concealment | 38 | 127 | 0.56 | (0.53, 0.59) | 1.09 | (1.07, 1.10) | -0.53 | (-0.56, -0.49)^*^
Similar baseline | 100 | 65 | 1.00 | (0.99, 1.02) | 0.87 | (0.83, 0.90) | 0.14 | (0.10, 0.17)^*^
Assessor blind | 157 | 8 | 1.00 | (0.98, 1.01) | 0.41 | (0.31, 0.51) | 0.59 | (0.49, 0.68)^*^
Care provider blind | 120 | 45 | 1.09 | (1.07, 1.10) | 0.14 | (0.10, 0.18) | 0.95 | (0.91, 0.99)^*^
Patient blind | 130 | 35 | 1.09 | (1.07, 1.10) | 0.08 | (0.04, 0.12) | 1.01 | (0.96, 1.05)^*^
Acceptable dropout rate | 96 | 69 | 1.15 | (1.13, 1.16) | 0.24 | (0.21, 0.27) | 0.90 | (0.87, 0.93)^*^
Original group (ITT) | 101 | 64 | 1.03 | (1.02, 1.04) | 0.40 | (0.35, 0.45) | 0.63 | (0.58, 0.68)^*^
Similar co-interventions | 142 | 23 | 1.02 | (1.00, 1.03) | 0.25 | (0.18, 0.31) | 0.77 | (0.71, 0.83)^*^
Acceptable compliance | 79 | 86 | 1.18 | (1.17, 1.20) | 0.29 | (0.27, 0.32) | 0.89 | (0.86, 0.92)^*^
Similar timing | 161 | 4 | 0.99 | (0.98, 1.01) | 0.28 | (0.15, 0.42) | 0.71 | (0.58, 0.84)^*^

* p<0.05

EPC = Evidence-based Practice Center; FE = based on fixed-effects model; ES = effect size; CI = confidence interval; ESdiff = effect size difference; ITT = intention to treat

Table D2 Comparison of different quality cutoffs using a total score (EPC reports), FE

Cutoff | Number Equal or Above Cut-off | Number Below Cutoff | High Quality | | Low Quality | | Difference
Cutoff | Number Equal or Above Cut-off | Number Below Cutoff | ES | 95% CI | ES | 95% CI | ESdiff | 95% CI
≥9 vs <9 | 42 | 123 | 1.22 | (1.21, 1.24) | 0.29 | (0.26, 0.31) | 0.93 | (0.91, 0.96)^*^
≥8 vs <8 | 65 | 100 | 1.16 | (1.15, 1.18) | 0.27 | (0.24, 0.30) | 0.89 | (0.86, 0.93)^*^
≥7 vs <7 | 103 | 62 | 1.03 | (1.02, 1.04) | 0.41 | (0.37, 0.46) | 0.62 | (0.57, 0.67)^*^
≥6 vs <6 | 135 | 30 | 1.01 | (1.00, 1.02) | 0.21 | (0.14, 0.28) | 0.80 | (0.73, 0.88)^*^
≥5 vs <5 | 149 | 16 | 1.00 | (0.99, 1.02) | 0.10 | (0.00, 0.20) | 0.90 | (0.80, 1.00)^*^
≥4 vs <4 | 160 | 5 | 0.99 | (0.98, 1.00) | 0.06 | (-0.16, 0.27) | 0.93 | (0.72, 1.15)

* p<0.05

EPC = Evidence-based Practice Center; FE = based on fixed effects model; ES = effect size; CI = confidence interval; ESdiff = effect size difference