# References Dataset 3: Published “Pro-bias” Dataset, 100 Trials

[no author]. A randomized trial of aspirin and sulfinpyrazone in threatened stroke. The Canadian Cooperative Study Group. N Engl J Med. Jul. 13. 1978;299(2):53-9. [pmid: 351394].
Baker RN. Anticoagulant therapy in cerebral infarction. Report on cooperative study. Neurology. Dec. 1962;12:823-35. [pmid: 13969171].
Baker RN, S W, Rose AS. Transient ischemic strokes. A Report of a study (cooperative) of anticoagulant therapy. Neurology. 1966;16:841-7.
Baldi F, Bianchi Porro G, Dobrilla G, Iascone C, Lobello R, Marzio L, et al. Cisapride versus placebo in reflux esophagitis. A multicenter double-blind trial. J Clin Gastroenterol. Dec. 1988;10(6):614-8. [pmid: 3068300].
Balzer K, Bechara G, Bisler H, Clevert HD, Diehm C, Heisig G, et al. Reduction of ischaemic rest pain in advanced peripheral arterial occlusive disease. A double blind placebo controlled trial with iloprost. Int Angiol. Oct-Dec. 1991;10(4):229-32. [pmid: 1724669].
Bjork K. The efficacy of zimeldine in preventing depressive episodes in recurrent major depressive disorders--a double-blind placebo-controlled study. Acta Psychiatr Scand Suppl. 1983;308:182-9. [pmid: 6230892].
Bliss WD, Campbell WB. Treatment of limb threatening ischaemia with intravenous iloprost: a randomised double-blind placebo controlled study. U.K. Severe Limb Ischaemia Study Group. Eur J Vasc Surg. Oct. 1991;5(5):511-6. [pmid: 1720403].
Bradshaw P, Brennan S. Trial of long-term anticoagulant therapy in the treatment of small stroke associated with a normal carotid arteriogram. J Neurol Neurosurg Psychiatry. Jul. 1975;38(7):642-7. [pmid: 1159434].
Breen KJ, Desmond PV, Whelan G. Treatment of reflux oesophagitis. A randomized, controlled evaluation of cimetidine. Med J Aust. Nov. 26. 1983;2(11):555-8. [pmid: 6355792].
Brock FE, Abri O, Baitsch G, Bechara G, Beck K, Corovic D, et al. Iloprost in the treatment of ischemic tissue lesions in diabetics. Results of a placebo-controlled multicenter study with a stable prostacyclin derivative. Schweiz Med Wochenschr. Oct. 6. 1990;120(40):1477-82. [pmid: 1699272].
Brown P. Cimetidine in the treatment of reflux oesophagitis. Med J Aust. Jul. 28. 1979;2(2):96-7. [pmid: 386063].
Burling TA, B G, Robinson JC, Mead AM. Smoking during pregnancy: reduction via objective assessment and directive advice. Behav Ther. 1991;22:31-40.
Campieri M, De Franchis R, Bianchi Porro G, Ranzi T, Brunetti G, Barbara L. Mesalazine (5-aminosalicylic acid) suppositories in the treatment of ulcerative proctitis or distal proctosigmoiditis. A randomized controlled trial. Scand J Gastroenterol. Jul. 1990;25(7):663-8. [pmid: 2204103].
Campieri M, Gionchetti P, Belluzzi A, Brignola C, Tampieri M, Iannone P, et al. Topical treatment with 5-aminosalicylic in distal ulcerative colitis by using a new suppository preparation. A double-blind placebo controlled trial. Int J Colorectal Dis. May. 1990;5(2):79-81. [pmid: 2193075].
Campieri M, Gionchetti P, Belluzzi A, Brignola C, Tampieri M, Iannone P, et al. Optimum dosage of 5-aminosalicylic acid as rectal enemas in patients with active ulcerative colitis. Gut. Aug. 1991;32(8):929-31. [pmid: 1885075].
Campieri M GP, Belluzzi A, et al. Sucra lfate, 5amlnosallcyllc acid, and placebo enemas In the treatment of distal ulcerative colltis. Eur J Gastroenterol Hepatol. 1991;3:41-4.
Carling L, Cronstedt J, Engqvist A, Kagevi I, Nystrom B, Svedberg LE, et al. Sucralfate versus placebo in reflux esophagitis. A double-blind multicenter study. Scand J Gastroenterol. Nov. 1988;23(9):1117-24. [pmid: 3073524].
Coppen A, Ghose K, Montgomery S, Rama Rao VA, Bailey J, Jorgensen A. Continuation therapy with amitriptyline in depression. Br J Psychiatry. Jul. 1978;133:28-33. [pmid: 352468].
Dew MJ, Hughes P, Harries AD, Williams G, Evans BK, Rhodes J. Maintenance of remission in ulcerative colitis with oral preparation of 5-aminosalicylic acid. Br Med J (Clin Res Ed). Oct. 9. 1982;285(6347):1012.
Diehm C, Abri O, Baitsch G, Bechara G, Beck K, Breddin HK, et al. Iloprost, a stable prostacyclin derivative, in stage 4 arterial occlusive disease. A placebo-controlled multicenter study. Dtsch Med Wochenschr. May. 19. 1989;114(20):783-8. [pmid: 2470569].
Duke RJ, Bloch RF, Turpie AG, Trebilcock R, Bayer N. Intravenous heparin for the prevention of stroke progression in acute partial stable stroke. Ann Intern Med. Dec. 1986;105(6):825-8. [pmid: 3535601].
Duke RJ, T A, Bloch RF, Trebilcock RG. Clinical trial of low-dose subcutaneous heparin for the prevention of stroke progression: natural history of acute partial stroke and stroke-in-evolution. Reivich M, H H, editors. Cerebrovascular Disease. New York. Raven Press. 1983:399-405.
Elias A, Milandre L, Lagrange G, Aillaud MF, Alonzo B, Toulemonde F, et al. Prevention of deep venous thrombosis of the leg by a very low molecular weight heparin fraction (CY 222) in patients with hemiplegia following cerebral infarction: a randomized pilot study (30 patients). Rev Med Interne. Jan-Feb. 1990;11(1):95-8. [pmid: 2158140].
Ershoff DH, Mullen PD, Quinn VP. A randomized trial of a serialized self-help smoking cessation program for pregnant women in an HMO. Am J Public Health. Feb. 1989;79(2):182-7. [pmid: 2913837].
Falloon IR, Boyd JL, McGill CW, Razani J, Moss HB, Gilderman AM. Family management in the prevention of exacerbations of schizophrenia: a controlled study. N Engl J Med. Jun. 17. 1982;306(24):1437-40. [pmid: 6123079].
Farup PG, Weberg R, Berstad A, Wetterhus S, Dahlberg O, Dybdahl J, et al. Low-dose antacids versus 400 mg cimetidine twice daily for reflux oesophagitis. A comparative, placebo-controlled, multicentre study. Scand J Gastroenterol. Mar. 1990;25(3):315-20. [pmid: 2181623].
Festen HP, Driessen WM, Lamers CB, Van Tongeren JH. Cimetidine in the treatment of severe ulcerative reflux oesophagitis; results of an 8-week double-blind study and of subsequent long-term maintenance treatment. Neth J Med. 1980;23(6):237-40. [pmid: 7007900].
Feurle GE, Theuer D, Velasco S, Barry BA, Wordehoff D, Sommer A, et al. Olsalazine versus placebo in the treatment of mild to moderate ulcerative colitis: a randomised double blind trial. Gut. Oct. 1989;30(10):1354-61. [pmid: 2684804].
Fiasse R, Hanin C, Lepot A, Descamps C, Lamy F, Dive C. Controlled trial of cimetidine in reflux esophagitis. Dig Dis Sci. Oct. 1980;25(10):750-5. [pmid: 7000475].
Fields WS, Lemak NA, Frankowski RF, Hardy RJ. Controlled trial of aspirin in cerebral ischemia. Stroke. May-Jun. 1977;8(3):301-14. [pmid: 324036].
Fields WS, Lemak NA, Frankowski RF, Hardy RJ. Controlled trial of aspirin in cerebral ischemia. Part II: surgical group. Stroke. Jul-Aug. 1978;9(4):309-19. [pmid: 354098].
Gielen. Personal Communication. [Personal Communication]. In press. 1993.
Gionchetti P, Campieri M, Belluzzi A, Brignola C, Tampieri M, Iannone P, et al. Pentasa in maintenance treatment of ulcerative colitis. Gastroenterology. Jan. 1990;98(1):251.
Glen AI, Johnson AL, Shepherd M. Continuation therapy with lithium and amitriptyline in unipolar depressive illness: a randomized, double-blind, controlled trial. Psychol Med. Feb. 1984;14(1):37-50. [pmid: 6143340].
Goy JA, Maynard JH, McNaughton WM, O'Shea A. Ranitidine and placebo in the treatment of reflux oesophagitis. A double-blind randomized trial. Med J Aust. Nov. 26. 1983;2(11):558-61. [pmid: 6314107].
Guilmot JL, D E. Treatment of lower limb ischaemia due to atherosclerosis in diabetic and non-diabetic patients with Iloprost, a stable analogue of prostacyclin: results of the French multicentre trial. Drug Investigation. 1991;3(5):351-9.
Hakim AM, Furlan AJ, Hart RG. Immediate anticoagulation of embolic stroke: a randomized trial. Cerebral Embolism Study Group. Stroke. 1983;14(5):668-76. [pmid: 6362091].
Hanauer S, Schwartz J, Roufall W, Robinson M, Cello J, Safdi M, et al. Dose-ranging study of oral mesalamine capsule (PENATASA) for active ulcerative colitis. Gastroenterology. Abstract. 1989;96:A195.
Harrison RF, O'Moore RR, McSweeney J. Idiopathic infertility: a trial of bromocriptine versus placebo. Ir Med J. Nov. 30. 1979;72(11):479-82. [pmid: 511486].
Hetzel DJ, Dent J, Reed WD, Narielvala FM, Mackinnon M, McCarthy JH, et al. Healing and relapse of severe peptic esophagitis after treatment with omeprazole. Gastroenterology. Oct. 1988;95(4):903-12. [pmid: 3044912].
Hetzel DJ, Shearman DJ, Bochner F, Imhoff DM, Gibson GE, Fitch RJ, et al. Azodisalicylate (olsalazine) in the treatment of active ulcerative colitis. A placebo controlled clinical trial and assessment of drug disposition. J Gastroent Hepatol. 1986;1:257-66.
Hjalmarson AI, Hahn L, Svanberg B. Stopping smoking in pregnancy: effect of a self-help manual in controlled trial. Br J Obstet Gynaecol. Mar. 1991;98(3):260-4. [pmid: 2021564].
Hogarty GE, Anderson CM, Reiss DJ, Kornblith SJ, Greenwald DP, Javna CD, et al. Family psychoeducation, social skills training, and maintenance chemotherapy in the aftercare treatment of schizophrenia. I. One-year effects of a controlled study on relapse and expressed emotion. Arch Gen Psychiatry. Jul. 1986;43(7):633-42. [pmid: 2872870].
Hull RD, Raskob GE, Pineo GF, Green D, Trowbridge AA, Elliott CG, et al. Subcutaneous low-molecular-weight heparin compared with continuous intravenous heparin in the treatment of proximal-vein thrombosis. N Engl J Med. Apr. 9. 1992;326(15):975-82. [pmid: 1545850].
Ireland A, Mason CH, Jewell DP. Controlled trial comparing olsalazine and sulphasalazine for the maintenance treatment of ulcerative colitis. Gut. Jun. 1988;29(6):835-7. [pmid: 2898422].
Jestico J, Harrison MJ, Marshall J. Trial of aspirin during weaning patients with transient ischaemic attacks from anticoagulants. Br Med J. May. 6. 1978;1(6121):1188.
Johansson KE, Boeryd B, Johansson K, Tibbling L. Double-blind crossover study of ranitidine and placebo in gastro-oesophageal reflux disease. Scand J Gastroenterol. Sep. 1986;21(7):769-78. [pmid: 3535004].
Kane JM, Quitkin FM, Rifkin A, Ramos-Lorenzi JR, Nayak DD, Howard A. Lithium carbonate and imipramine in the prophylaxis of unipolar and bipolar II illness: a prospective, placebo-controlled comparison. Arch Gen Psychiatry. Sep. 1982;39(9):1065-9. [pmid: 6810839].
Kiilerich S, Ladefoged K, Rannem T, Ranlov PJ. Prophylactic effects of olsalazine v sulphasalazine during 12 months maintenance treatment of ulcerative colitis. The Danish Olsalazine Study Group. Gut. Feb. 1992;33(2):252-5. [pmid: 1347280].
Klerman GL, Dimascio A, Weissman M, Prusoff B, Paykel ES. Treatment of depression by drugs and psychotherapy. Am J Psychiatry. Feb. 1974;131(2):186-91. [pmid: 4587807].
Leff J, Kuipers L, Berkowitz R, Sturgeon D. A controlled trial of social intervention in the families of schizophrenic patients: two year follow-up. Br J Psychiatry. Jun. 1985;146:594-600. [pmid: 3893605].
Lehtola J, Niemela S, Martikainen J, Krekela I. Ranitidine, 150 mg three times a day, in the treatment of reflux oesophagitis. A placebo-controlled, double-blind study. Scand J Gastroenterol. Mar. 1986;21(2):175-80. [pmid: 3520796].
Lepoutre L, Van der Spek P, Vanderlinden I, Bollen J, Laukens P. Healing of grade-II and III oesophagitis through motility stimulation with cisapride. Digestion. 1990;45(2):109-14. [pmid: 2190850].
Lepsien G, Sonnenberg A, Berges W, Weber KB, Wienbeck M, Siewert JR, et al. Treatment of reflux oesophagitis with cimetidine (author's transl). Dtsch Med Wochenschr. Jun. 22. 1979;104(25):901-6. [pmid: 446319].
Lindmarker P, Holmstrom M, Granqvist S, Johnsson H, Lockner D. Comparison of once-daily subcutaneous Fragmin with continuous intravenous unfractionated heparin in the treatment of deep vein thrombosis. Thromb Haemost. Aug. 1994;72(2):186-90. [pmid: 7831649].
Lopaciuk S, Meissner AJ, Filipecki S, Zawilska K, Sowier J, Ciesielski L, et al. Subcutaneous low molecular weight heparin versus subcutaneous unfractionated heparin in the treatment of deep vein thrombosis: a Polish multicenter trial. Thromb Haemost. Jul. 6. 1992;68(1):14-8. [pmid: 1325076].
Marshall J, Shaw DA. Anticoagulant therapy in acute cerebrovascular accidents. A controlled trial. Lancet. May. 7. 1960;1(7132):995-8. [pmid: 14421533].
McBain JC, Pepperell RJ. Use of bromocriptine in unexplained infertility. Clin Reprod Fertil. Jun. 1982;1(2):145-50. [pmid: 6764750].
McCallum RW, Fink SM, Winnan GR, Avella J, Callachan C. Metoclopramide in gastroesophageal reflux disease: rationale for its use and results of a double-blind trial. Am J Gastroenterol. Mar. 1984;79(3):165-72. [pmid: 6367434].
McIntyre PB, Rodrigues CA, Lennard-Jones JE, Barrison IG, Walker JG, Baron JH, et al. Balsalazide in the maintenance treatment of patients with ulcerative colitis, a double-blind comparison with sulphasalazine. Aliment Pharmacol Ther. Jun. 1988;2(3):237-43. [pmid: 2908755].
Mindham RH, Howland C, Shepherd M. An evaluation of continuation therapy with tricyclic antidepressants in depressive illness. Psychol Med. Feb. 1973;3(1):5-17. [pmid: 4571148].
Montgomery SA, Dufour H, Brion S, Gailledreau J, Laqueille X, Ferrey G, et al. The prophylactic efficacy of fluoxetine in unipolar depression. Br J Psychiatry Suppl. Sep. 1988;(3):69-76. [pmid: 3150694].
Mulder CJ, Tytgat GN, Weterman IT, Dekker W, Blok P, Schrijver M, et al. Double-blind comparison of slow-release 5-aminosalicylate and sulfasalazine in remission maintenance in ulcerative colitis. Gastroenterology. Dec. 1988;95(6):1449-53. [pmid: 2903110].
Niemela S, Jaaskelainen T, Lehtola J, Martikainen J, Krekela I, Sarna S, et al. Pirenzepine in the treatment of reflux oesophagitis. A placebo-controlled, double-blind study. Scand J Gastroenterol. Dec. 1986;21(10):1193-9. [pmid: 3544181].
Norgren L, Alwmark A, Angqvist KA, Hedberg B, Bergqvist D, Takolander R, et al. A stable prostacyclin analogue (iloprost) in the treatment of ischaemic ulcers of the lower limb. A Scandinavian-Polish placebo controlled, randomised multicenter study. Eur J Vasc Surg. Oct. 1990;4(5):463-7. [pmid: 1699814].
O'Connor AM, Davies BL, Dulberg CS, Buhler PL, Nadon C, McBride BH, et al. Effectiveness of a pregnancy smoking cessation program. J Obstet Gynecol Neonatal Nurs. Sep-Oct. 1992;21(5):385-92.
Palmer RH, Frank WO, Rockhold FW, Wetherington JD, Young MD. Cimetidine 800 mg twice daily for healing erosions and ulcers in gastroesophageal reflux disease. J Clin Gastroenterol. 2. 1990;12:S29-34. [pmid: 2246493].
Pearce JM, Gubbay SS, Walton JN. Long-Term Anticoagulant Therapy in Transient Cerebral Ischaemic Attacks. Lancet. Jan. 2. 1965;1(7375):6-9. [pmid: 14246697].
Petersen L, Handel J, Kotch J, Podedworny T, Rosen A. Smoking reduction during pregnancy by a program of self-help and clinical support. Obstet Gynecol. Jun. 1992;79(6):924-30. [pmid: 1579315].
Pince J. Thromboses veineuses des membres inferieurs et embolies pulmonaires au cours des accidents vasculaires cerebraux. A propos d'un essai comparitif de traitement preventif (These pour le doctorat d'etat en medecine). In press. 1981.
Prandoni P, Lensing AW, Buller HR, Carta M, Cogo A, Vigo M, et al. Comparison of subcutaneous low-molecular-weight heparin with intravenous standard heparin in proximal deep-vein thrombosis. Lancet. Feb. 22. 1992;339(8791):441-5. [pmid: 1346817].
Price JH, Krol RA, Desmond SM, Losh DP, Roberts SM, Snyder FF. Comparison of three antismoking interventions among pregnant women in an urban setting: a randomized trial. Psychol Rep. Apr. 1991;68(2):595-604. [pmid: 1862191].
Prins MH, Gelsema R, Sing AK, van Heerde LR, den Ottolander GJ. Prophylaxis of deep venous thrombosis with a low-molecular-weight heparin (Kabi 2165/Fragmin) in stroke patients. Haemostasis. 1989;19(5):245-50. [pmid: 2550335].
Quik RF, Cooper MJ, Gleeson M, Hentschel E, Schuetze K, Kingston RD, et al. A comparison of two doses of nizatidine versus placebo in the treatment of reflux oesophagitis. Aliment Pharmacol Ther. Apr. 1990;4(2):201-11. [pmid: 1983322].
Reuther R, D W. Aspirin in patients with cerebral ischaemia and normal angiograms or non-surgical lesions. Acetylsalicylic Acid in Cerebral Ischaemia and Coronary Heart Disease. 1978:97-106.
Rijk MC, van Lier HJ, van Tongeren JH. Relapse-preventing effect and safety of sulfasalazine and olsalazine in patients with ulcerative colitis in remission: a prospective, double-blind, randomized multicenter study. The Ulcerative Colitis Multicenter Study Group. Am J Gastroenterol. Apr. 1992;87(4):438-42. [pmid: 1348159].
Riley SA, Mani V, Goodman MJ, Herd ME, Dutt S, Turnberg LA. Comparison of delayed-release 5-aminosalicylic acid (mesalazine) and sulfasalazine as maintenance treatment for patients with ulcerative colitis. Gastroenterology. Jun. 1988;94(6):1383-9. [pmid: 2896139].
Rutgeerts P. Comparative efficacy of coated, oral 5-aminosalicylic acid (Claversal) and sulphasalazine for maintaining remission of ulcerative colitis. International Study Group. Aliment Pharmacol Ther. Apr. 1989;3(2):183-91. [pmid: 2577483].
Sandset PM, Dahl T, Stiris M, Rostad B, Scheel B, Abildgaard U. A double-blind and randomized placebo-controlled trial of low molecular weight heparin once daily to prevent deep-vein thrombosis in acute ischemic stroke. Semin Thromb Hemost. Oct. Suppl. 1990;16:25-33. [pmid: 1962901].
Schroeder KW, Tremaine WJ, Ilstrup DM. Coated oral 5-aminosalicylic acid therapy for mildly to moderately active ulcerative colitis. A randomized study. N Engl J Med. Dec. 24. 1987;317(26):1625-9. [pmid: 3317057].
Seager CP, Bird RL. Imipramine with electrical treatment in depression--a controlled trial. J Ment Sci. Sep. 1962;108:704-7. [pmid: 13987497].
Secker-Walker RH, Solomon LJ, Flynn BS, Skelly JM, Lepage SS, Goodwin GD, et al. Individualized smoking cessation counseling during prenatal and early postnatal care. Am J Obstet Gynecol. Nov. 1994;171(5):1347-55. [pmid: 7977545].
Sexton M, Hebel JR. A clinical trial of change in maternal smoking and its effect on birth weight. JAMA. Feb. 17. 1984;251(7):911-5. [pmid: 6363731].
Sherbaniuk R, Wensel R, Bailey R, Trautman A, Grace M, Kirdeikis P, et al. Ranitidine in the treatment of symptomatic gastroesophageal reflux disease. J Clin Gastroenterol. Feb. 1984;6(1):9-15. [pmid: 6321588].
Simonneau G, Charbonnier B, Decousus H, Planchon B, Ninet J, Sie P, et al. Subcutaneous low-molecular-weight heparin compared with continuous intravenous unfractionated heparin in the treatment of proximal deep vein thrombosis. Arch Intern Med. Jul. 12. 1993;153(13):1541-6. [pmid: 8391792].
Sninsky CA, Cort DH, Shanahan F, Powers BJ, Sessions JT, Pruitt RE, et al. Oral mesalamine (Asacol) for mildly to moderately active ulcerative colitis. A multicenter study. Ann Intern Med. Sep. 1. 1991;115(5):350-5. [pmid: 1863024].
Sontag S, Robinson M, McCallum RW, Barwick KW, Nardi R. Ranitidine therapy for gastroesophageal reflux disease. Results of a large double-blind trial. Arch Intern Med. Aug. 1987;147(8):1485-91. [pmid: 3307670].
Sorensen PS, Pedersen H, Marquardsen J, Petersson H, Heltberg A, Simonsen N, et al. Acetylsalicylic acid in the prevention of stroke in patients with reversible cerebral ischemic attacks. A Danish cooperative study. Stroke. Jan-Feb. 1983;14(1):15-22. [pmid: 6337425].
Stein MK, Rickels K, Weise CC. Maintenance therapy with amitriptyline: a controlled trial. Am J Psychiatry. Mar. 1980;137(3):370-1. [pmid: 6986799].
Sutherland LR, Martin F, Greer S, Robinson M, Greenberger N, Saibil F, et al. 5-Aminosalicylic acid enema in the treatment of distal ulcerative colitis, proctosigmoiditis, and proctitis. Gastroenterology. Jun. 1987;92(6):1894-8. [pmid: 3569765].
Sutherland LR, Robinson M, Onstad G, Peppercorn M, Greenberger N, Goodman M, et al. A double-blind, placebo controlled, multicentre study of the efficacy and safety of 5-aminosalicylic acid tablets in the treatment of ulcerative colitis. Can J Gastroenterol. 1990;4:463-7.
Tarrier N, Barrowclough C, Vaughn C, Bamrah JS, Porceddu K, Watts S, et al. The community management of schizophrenia. A controlled trial of a behavioural intervention with families to reduce relapse. Br J Psychiatry. Oct. 1988;153:532-42. [pmid: 3074860].
Turpie AG, Levine MN, Hirsh J, Carter CJ, Jay RM, Powers PJ, et al. Double-blind randomised trial of Org 10172 low-molecular-weight heparinoid in prevention of deep-vein thrombosis in thrombotic stroke. Lancet. Mar. 7. 1987;1(8532):523-6. [pmid: 2434815].
Vaughan K, Doyle M, McConaghy N, Blaszczynski A, Fox A, Tarrier N. The Sydney intervention trial: a controlled trial of relatives' counselling to reduce schizophrenic relapse. Soc Psychiatry Psychiatr Epidemiol. Jan. 1992;27(1):16-21. [pmid: 1557677].
Weiss. Klinische Erfahrungen mit Ulcogant bei der Reflux-oesophagitis. Swiss Med. 1983;5:21-4.
Wesdorp E, Bartelsman J, Pape K, Dekker W, Tytgat GN. Oral cimetidine in reflux esophagitis: a double blind controlled trial. Gastroenterology. May. 1978;74(5 Pt 1):821-4. [pmid: 346430].
Wesdorp IC, Dekker W, Klinkenberg-Knol EC. Treatment of reflux oesophagitis with ranitidine. Gut. Oct. 1983;24(10):921-4. [pmid: 6311693].
Windsor RA, Cutter G, Morris J, Reese Y, Manzella B, Bartlett EE, et al. The effectiveness of smoking cessation methods for smokers in public health maternity clinics: a randomized trial. Am J Public Health. Dec. 1985;75(12):1389-92. [pmid: 4061709].
Windsor RA, Lowe JB, Perkins LL, Smith-Yoder D, Artz L, Crawford M, et al. Health education for pregnant smokers: its behavioral impact and cost benefit. Am J Public Health. Feb. 1993;83(2):201-6. [pmid: 8427323].
Wright CS, Steele SJ, Jacobs HS. Value of bromocriptine in unexplained primary infertility: a double-blind controlled trial. Br Med J. Apr. 21. 1979;1(6170):1037-9. [pmid: 376036].