# References Dataset 2: EPC Reports, 165 Trials

[no author]. Gabapentin in partial epilepsy. UK Gabapentin Study Group. Lancet. May. 12. 1990;335(8698):1114-7. [pmid: 1971862].
[no author]. Efficacy of felbamate in childhood epileptic encephalopathy (Lennox-Gastaut syndrome). The Felbamate Study Group in Lennox-Gastaut Syndrome. N Engl J Med. Jan. 7. 1993;328(1):29-33. [pmid: 8347179].
[no author]. Dietary supplementation with n-3 polyunsaturated fatty acids and vitamin E after myocardial infarction: results of the GISSI-Prevenzione trial. Gruppo Italiano per lo Studio della Sopravvivenza nell'Infarto miocardico. Lancet. Aug. 7. 1999;354(9177):447-55. [pmid: 10465168].
[no author]. Topiramate in medically intractable partial epilepsies: double-blind placebo-controlled randomized parallel group trial. Korean Topiramate Study Group. Epilepsia. Dec. 1999;40(12):1767-74. [pmid: 10612342].
Altman RD, Moskowitz R. Intraarticular sodium hyaluronate (Hyalgan) in the treatment of patients with osteoarthritis of the knee: a randomized clinical trial. Hyalgan Study Group. J Rheumatol. Nov. 1998;25(11):2203-12. [pmid: 9818665].
Ancarani E, Biondi B, Bolletta A, Cestra D, De Bella E, Nirchi M, et al. Major depression complicating hemodialysis in patients with chronic renal failure: A multicenter, double-blind, controlled clinical trial of s-adenosyl-l-methionine versus placebo. Current Therapeutic Research. 1993;54(6):680-6.
Anderson RA, Cheng N, Bryden NA, Polansky MM, Chi J, Feng J. Elevated intakes of supplemental chromium improve glucose and insulin variables in individuals with type 2 diabetes. Diabetes. Nov. 1997;46(11):1786-91. [pmid: 9356027].
Angerer P, Kothny W, Stork S, von Schacky C. Effect of dietary supplementation with omega-3 fatty acids on progression of atherosclerosis in carotid arteries. Cardiovasc Res. Apr. 2002;54(1):183-90. [pmid: 12062374].
Anhut H, Ashman P, Feuerstein TJ, Sauermann W, Saunders M, Schmidt B. Gabapentin (Neurontin) as add-on therapy in patients with partial seizures: a double-blind, placebo-controlled study. The International Gabapentin Study Group. Epilepsia. Jul-Aug. 1994;35(4):795-801. [pmid: 8082624].
Antoni CE, Kavanaugh A, Kirkham B, Tutuncu Z, Burmester GR, Schneider U, et al. Sustained benefits of infliximab therapy for dermatologic and articular manifestations of psoriatic arthritis: results from the infliximab multinational psoriatic arthritis controlled trial (IMPACT). Arthritis Rheum. Apr. 2005;52(4):1227-36. [pmid: 15818699].
Appleton R, Fichtner K, LaMoreaux L, Alexander J, Halsall G, Murray G, et al. Gabapentin as add-on therapy in children with refractory partial seizures: a 12-week, multicentre, double-blind, placebo-controlled study. Gabapentin Paediatric Study Group. Epilepsia. Aug. 1999;40(8):1147-54. [pmid: 10448830].
Atmaca M, Kuloglu M, Tezcan E, Gecici O. Quetiapine augmentation in patients with treatment resistant obsessive-compulsive disorder: a single-blind, placebo-controlled study. Int Clin Psychopharmacol. May. 2002;17(3):115-9. [pmid: 11981352].
Bairati I, Roy L, Meyer F. Effects of a fish oil supplement on blood pressure and serum lipids in patients treated for coronary artery disease. Can J Cardiol. Jan-Feb. 1992;8(1):41-6. [pmid: 1617510].
Bakris G, Calhoun D, Egan B, Hellmann C, Dolker M, Kingma I. Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. Nov. 2002;20(11):2257-67. [pmid: 12409965].
Ben-Menachem E, Falter U. Efficacy and tolerability of levetiracetam 3000 mg/d in patients with refractory partial seizures: a multicenter, double-blind, responder-selected study evaluating monotherapy. European Levetiracetam Study Group. Epilepsia. Oct. 2000;41(10):1276-83. [pmid: 11051122].
Ben-Menachem E, Henriksen O, Dam M, Mikkelsen M, Schmidt D, Reid S, et al. Double-blind, placebo-controlled trial of topiramate as add-on therapy in patients with refractory partial seizures. Epilepsia. Jun. 1996;37(6):539-43. [pmid: 8641230].
Betts T, Waegemans T, Crawford P. A multicentre, double-blind, randomized, parallel group study to evaluate the tolerability and efficacy of two oral doses of levetiracetam, 2000 mg daily and 4000 mg daily, without titration in patients with refractory epilepsy. Seizure. Mar. 2000;9(2):80-7. [pmid: 10845730].
Biton V, Montouris GD, Ritter F, Riviello JJ, Reife R, Lim P, et al. A randomized, placebo-controlled study of topiramate in primary generalized tonic-clonic seizures. Topiramate YTC Study Group. Neurology. Apr. 22. 1999;52(7):1330-7. [pmid: 10227614].
Bonaa KH, Bjerve KS, Nordoy A. Docosahexaenoic and eicosapentaenoic acids in plasma phospholipids are divergently associated with high density lipoprotein in humans. Arterioscler Thromb. Jun. 1992;12(6):675-81. [pmid: 1534256].
Brandt KD, Block JA, Michalski JP, Moreland LW, Caldwell JR, Lavin PT. Efficacy and safety of intraarticular sodium hyaluronate in knee osteoarthritis. ORTHOVISC Study Group. Clin Orthop Relat Res. Apr. 2001;(385):130-43. [pmid: 11302304].
Brodaty H, Corey-Bloom J, Potocnik FC, Truyen L, Gold M, Damaraju CR. Galantamine prolonged-release formulation in the treatment of mild to moderate Alzheimer's disease. Dement Geriatr Cogn Disord. 2005;20(2-3):120-32. [pmid: 15990426].
Broom I, Wilding J, Stott P, Myers N. Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002. Sep. 2002;56(7):494-9. [pmid: 12296610].
Brown KM, Morrice PC, Duthie GG. Vitamin E supplementation suppresses indexes of lipid peroxidation and platelet counts in blood of smokers and nonsmokers but plasma lipoprotein concentrations remain unchanged. Am J Clin Nutr. Sep. 1994;60(3):383-7. [pmid: 8074069].
Brown SA, Garcia AA, Kouzekanani K, Hanis CL. Culturally competent diabetes self-management education for Mexican Americans: the Starr County border health initiative. Diabetes Care. Feb. 2002;25(2):259-68. [pmid: 11815493].
Brox J, Olaussen K, Osterud B, Elvevoll EO, Bjornstad E, Brattebog G, et al. A long-term seal- and cod-liver-oil supplementation in hypercholesterolemic subjects. Lipids. Jan. 2001;36(1):7-13. [pmid: 11214732].
Bystritsky A, Ackerman DL, Rosen RM, Vapnik T, Gorbis E, Maidment KM, et al. Augmentation of serotonin reuptake inhibitors in refractory obsessive-compulsive disorder using adjunctive olanzapine: a placebo-controlled trial. J Clin Psychiatry. Apr. 2004;65(4):565-8. [pmid: 15119922].
Cairns JA, Gill J, Morton B, Roberts R, Gent M, Hirsh J, et al. Fish oils and low-molecular-weight heparin for the reduction of restenosis after percutaneous transluminal coronary angioplasty. The EMPAR Study. Circulation. Oct. 1. 1996;94(7):1553-60. [pmid: 8840843].
Carey PD, Vythilingum B, Seedat S, Muller JE, van Ameringen M, Stein DJ. Quetiapine augmentation of SRIs in treatment refractory obsessive-compulsive disorder: a double-blind, randomised, placebo-controlled study [ISRCTN83050762]. BMC Psychiatry. 2005;5:5. [pmid: 15667657].
Carney MW, Edeh J, Bottiglieri T, Reynolds EM, Toone BK. Affective illness and S-adenosyl methionine: a preliminary report. Clin Neuropharmacol. 1986;9(4):379-85. [pmid: 2425961].
Carrabba M, Paresce E, Angelini M, Re KA, Tochiana EEM, Perbellini A. The safety and efficacy of different dose schedules of hyaluronic acid in the treatment of painful osteoarthritis of the knee with joint effusion. Eur J Rheumatol Inflamm. 1995;15:25-31.
Carrieri P, Indaco A, Gentile S, Troisi E, Campanella G. S-adenosylmethionine treatment of depression in patients with parkinson's disease. Current Therapeutic Research. 1990;48(1):154-60.
Caruso I, Fumagaili M, Boccassini L, Sarzi Puttin P, Santandrea S, Ciniseili G, et al. Treatment of depression in rheumatoid arthritic patients: A comparison of S-Adenosylmethinine (Samyr*) and placebo in a double-blind study. Clinical Trials Journal. 1987;24(4):305-10.
Cereghino JJ, Biton V, Abou-Khalil B, Dreifuss F, Gauer LJ, Leppik I. Levetiracetam for partial seizures: results of a double-blind, randomized clinical trial. Neurology. Jul. 25. 2000;55(2):236-42. [pmid: 10908898].
Chadwick D, Leiderman DB, Sauermann W, Alexander J, Garofalo E. Gabapentin in generalized seizures. Epilepsy Res. Nov. 1996;25(3):191-7. [pmid: 8956916].
Cohen MA, Shiroky JB, Ballechey ML, Neville C, Esdaile JM. Double-blind randomized trial of Intra-articular Hyaluronate in the treatment of osteoarthritis of the knee. Arthritis Rheum. 1994;34(6).
Corey-Bloom J, Anand JV, Veach J. A randomized trial evaluating the efficacy and safety of ENA 713 (rivastigmine tartrate), a new acetylcholinesterase inhibitor, in patients with mild to moderately severe Alzheimer's disease. Int J Geriatr Psychopharmacol. 1998;1:55-65.
Corrado E, Peluso GF, Gigliotti S. The effects of intra-articular administrationof hyaluronic acid on osteoarthritis of the knee: a clinical study with immunological and biochemical evaluations. Eur J Rheumatol Inflamm. 1995;15:47-56.
Creamer P, Sharif M, George E, Meadows K, Cushnaghan J, Shinmei M, et al. Intra-articular hyaluronic acid in osteoarthritis of the knee: an investigation into mechanisms of action. Osteoarthritis Cartilage. Jun. 1994;2(2):133-40. [pmid: 11548229].
Dahlberg L, Lohmander LS, Ryd L. Intraarticular injections of hyaluronan in patients with cartilage abnormalities and knee pain. A one-year double-blind, placebo-controlled study. Arthritis Rheum. Apr. 1994;37(4):521-8. [pmid: 8147929].
Davidson M, Hauptman J, DiGirolamo M, Foreyt J, Halsted C, Heber D, et al. Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. Jan. 20. 1999;281(3):235-42. [pmid: 9918478].
Davidson MB, Castellanos M, Kain D, Duran P. The effect of self monitoring of blood glucose concentrations on glycated hemoglobin levels in diabetic patients not taking insulin: a blinded, randomized trial. Am J Med. Apr. 2005;118(4):422-5. [pmid: 15808142].
De Leo D. S-adenosylmethionine as an antidepressant: A double-blind trial versus placebo. Current Therapeutic Research. 1987;41(6):865-70.
de Waart FG, Moser U, Kok FJ. Vitamin E supplementation in elderly lowers the oxidation rate of linoleic acid in LDL. Atherosclerosis. Sep. 1997;133(2):255-63. [pmid: 9298686].
Delle Chiaie R, Boissard G. Ademetionine (same) for the treatment of major depression: Meta-analysis of two european multicenter controlled trials. Pharmacol Res. 1997;35(108):108.
DeMaio SJ, King SB 3rd, Lembo NJ, Roubin GS, Hearn JA, Bhagavan HN, et al. Vitamin E supplementation, plasma lipids and incidence of restenosis after percutaneous transluminal coronary angioplasty (PTCA). J Am Coll Nutr. Feb. 1992;11(1):68-73. [pmid: 1541798].
Denys D, de Geus F, van Megen HJ, Westenberg HG. A double-blind, randomized, placebo-controlled trial of quetiapine addition in patients with obsessive-compulsive disorder refractory to serotonin reuptake inhibitors. J Clin Psychiatry. Aug. 2004;65(8):1040-8. [pmid: 15323587].
D'Eramo-Melkus GA, Wylie-Rosett J, Hagan JA. Metabolic impact of education in NIDDM. Diabetes Care. Jul. 1992;15(7):864-9. [pmid: 1516506].
Derosa G, Mugellini A, Ciccarelli L, Fogari R. Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003. Apr. 2003;25(4):1107-22. [pmid: 12809960].
Dixon AS, Jacoby RK, Berry H, Hamilton EB. Clinical trial of intra-articular injection of sodium hyaluronate in patients with osteoarthritis of the knee. Curr Med Res Opin. 1988;11(4):205-13. [pmid: 3063436].
Dougados M, Nguyen M, Listrat V, Amor B. High molecular weight sodium hyaluronate (hyalectin) in osteoarthritis of the knee: a 1 year placebo-controlled trial. Osteoarthritis Cartilage. Apr. 1993;1(2):97-103. [pmid: 8886085].
Duchowny M, Pellock JM, Graf WD, Billard C, Gilman J, Casale E, et al. A placebo-controlled trial of lamotrigine add-on therapy for partial seizures in children. Lamictal Pediatric Partial Seizure Study Group. Neurology. Nov. 10. 1999;53(8):1724-31. [pmid: 10563619].
Elterman RD, Glauser TA, Wyllie E, Reife R, Wu SC, Pledger G. A double-blind, randomized trial of topiramate as adjunctive therapy for partial-onset seizures in children. Topiramate YP Study Group. Neurology. Apr. 22. 1999;52(7):1338-44. [pmid: 10227615].
Eritsland J, Arnesen H, Seljeflot I, Hostmark AT. Long-term metabolic effects of n-3 polyunsaturated fatty acids in patients with coronary artery disease. Am J Clin Nutr. Apr. 1995;61(4):831-6. [pmid: 7702027].
Erzegovesi S, Guglielmo E, Siliprandi F, Bellodi L. Low-dose risperidone augmentation of fluvoxamine treatment in obsessive-compulsive disorder: a double-blind, placebo-controlled study. Eur Neuropsychopharmacol. Jan. 2005;15(1):69-74. [pmid: 15572275].
Evans GW. The effect of chromium picolinate on insulin controlled parameters in humans. Int J Biosoc Med Res. 1989;11:163-80.
Falkenberg MG, Elwing BE, Goransson AM, Hellstrand BE, Riis UM. Problem oriented participatory education in the guidance of adults with non-insulin-treated type-II diabetes mellitus. Scand J Prim Health Care. Sep. 1986;4(3):157-64. [pmid: 3775139].
Farmer A, Wade A, Goyder E, Yudkin P, French D, Craven A, et al. Impact of self monitoring of blood glucose in the management of patients with non-insulin treated diabetes: open parallel group randomised trial. BMJ. Jul. 21. 2007;335(7611):132. [pmid: 17591623].
Faught E, Ayala R, Montouris GG, Leppik IE. Randomized controlled trial of zonisamide for the treatment of refractory partial-onset seizures. Neurology. Nov. 27. 2001;57(10):1774-9. [pmid: 11723262].
Faught E, Wilder BJ, Ramsay RE, Reife RA, Kramer LD, Pledger GW, et al. Topiramate placebo-controlled dose-ranging trial in refractory partial epilepsy using 200-, 400-, and 600-mg daily dosages. Topiramate YD Study Group. Neurology. Jun. 1996;46(6):1684-90. [pmid: 8649570].
Fava M, Rosenbaum JF, Birnbaum R, Kelly K, Otto MW, MacLaughlin R. The thyrotropin response to thyrotropin-releasing hormone as a predictor of response to treatment in depressed outpatients. Acta Psychiatr Scand. Jul. 1992;86(1):42-5. [pmid: 1414398].
Fineberg NA, Sivakumaran T, Roberts A, Gale T. Adding quetiapine to SRI in treatment-resistant obsessive-compulsive disorder: a randomized controlled treatment study. Int Clin Psychopharmacol. Jul. 2005;20(4):223-6. [pmid: 15933483].
Finnegan YE, Minihane AM, Leigh-Firbank EC, Kew S, Meijer GW, Muggli R, et al. Plant- and marine-derived n-3 polyunsaturated fatty acids have differential effects on fasting and postprandial blood lipid concentrations and on the susceptibility of LDL to oxidative modification in moderately hyperlipidemic subjects. Am J Clin Nutr. Apr. 2003;77(4):783-95. [pmid: 12663273].
Fontbonne A, Billault B, Acosta M, Percheron C, Varenne P, Besse A, et al. Is glucose self-monitoring beneficial in non-insulin-treated diabetic patients? Results of a randomized comparative trial. Diabete Metab. Sep-Oct. 1989;15(5):255-60. [pmid: 2630378].
Franzen D, Schannwell M, Oette K, Hopp HW. A prospective, randomized, and double-blind trial on the effect of fish oil on the incidence of restenosis following PTCA. Cathet Cardiovasc Diagn. Apr. 1993;28(4):301-10. [pmid: 8462079].
Fuller CJ, Chandalia M, Garg A, Grundy SM, Jialal I. RRR-alpha-tocopheryl acetate supplementation at pharmacologic doses decreases low-density-lipoprotein oxidative susceptibility but not protein glycation in patients with diabetes mellitus. Am J Clin Nutr. May. 1996;63(5):753-9. [pmid: 8615360].
Ghosh D, Bhattacharya B, Mukherjee B, Manna B, Sinha M, Chowdhury J, et al. Role of chromium supplementation in Indians with type 2 diabetes mellitus. J Nutr Biochem. Nov. 2002;13(11):690-7. [pmid: 12550067].
Glasgow RE, Toobert DJ, Hampson SE, Brown JE, Lewinsohn PM, Donnelly J. Improving self-care among older patients with type II diabetes: the “Sixty Something…” Study. Patient Educ Couns. Feb. 1992;19(1):61-74. [pmid: 1298950].
Glauser TA, Nigro M, Sachdeo R, Pasteris LA, Weinstein S, Abou-Khalil B, et al. Adjunctive therapy with oxcarbazepine in children with partial seizures. The Oxcarbazepine Pediatric Study Group. Neurology. Jun. 27. 2000;54(12):2237-44. [pmid: 10881246].
Goudswaard AN, Stolk RP, Zuithoff NP, de Valk HW, Rutten GE. Long-term effects of self-management education for patients with Type 2 diabetes taking maximal oral hypoglycaemic therapy: a randomized trial in primary care. Diabet Med. May. 2004;21(5):491-6. [pmid: 15089797].
Greenfield S, Kaplan SH, Ware JE Jr, Yano EM, Frank HJ. Patients' participation in medical care: effects on blood sugar control and quality of life in diabetes. J Gen Intern Med. Sep-Oct. 1988;3(5):448-57. [pmid: 3049968].
Grimsgaard S, Bonaa KH, Hansen JB, Nordoy A. Highly purified eicosapentaenoic acid and docosahexaenoic acid in humans have similar triacylglycerol-lowering effects but divergent effects on serum fatty acids. Am J Clin Nutr. Sep. 1997;66(3):649-59. [pmid: 9280188].
Guerci B, Drouin P, Grange V, Bougneres P, Fontaine P, Kerlan V, et al. Self-monitoring of blood glucose significantly improves metabolic control in patients with type 2 diabetes mellitus: the Auto-Surveillance Intervention Active (ASIA) study. Diabetes Metab. Dec. 2003;29(6):587-94. [pmid: 14707887].
Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. Nov. 2002;4(6):415-23. [pmid: 12406041].
Hauptman J, Lucas C, Boldrin M, Collins H, Segal K. Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. Feb. 2000;9(2):160-7. [pmid: 10693734].
Henderson EB, Smith EC, Pegley F, Blake DR. Intra-articular injections of 750 kD hyaluronan in the treatment of osteoarthritis: a randomised single centre double-blind placebo-controlled trial of 91 patients demonstrating lack of efficacy. Ann Rheum Dis. Aug. 1994;53(8):529-34. [pmid: 7944639].
Hill J, Hauptman J, Anderson J, Fujioka K, O'Neil P, Smith D, et al. Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. Jun. 1999;69(6):1108-16. [pmid: 10357727].
Hoffman RM, Garewal HS. Alpha-tocopherol supplementation for men with existing coronary artery disease: a feasibility study. Prev Med. Aug. 1999;29(2):112-8. [pmid: 10446037].
Hollander E, Baldini Rossi N, Sood E, Pallanti S. Risperidone augmentation in treatment-resistant obsessive-compulsive disorder: a double-blind, placebo-controlled study. Int J Neuropsychopharmacol. Dec. 2003;6(4):397-401. [pmid: 14604454].
Hollander P, Elbein S, Hirsch I, Kelley D, McGill J, Taylor T, et al. Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. 1998. Aug. 1998;21(8):1288-94. [pmid: 9702435].
Homma A, Takeda M, Imai Y, Udaka F, Hasegawa K, Kameyama M, et al. Clinical efficacy and safety of donepezil on cognitive and global function in patients with Alzheimer's disease A 24-week, multicenter, double-blind, placebo-controlled study in Japan. E2020 Study Group. Dement Geriatr Cogn Disord. Nov-Dec. 2000;11(6):299-313. [pmid: 11044775].
Huskisson EC, Donnelly S. Hyaluronic acid in the treatment of osteoarthritis of the knee. Rheumatology (Oxford). Jul. 1999;38(7):602-7. [pmid: 10461471].
Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. Mar. 1996;30(3):238-43. [pmid: 8833557].
Jaber LA, Halapy H, Fernet M, Tummalapalli S, Diwakaran H. Evaluation of a pharmaceutical care model on diabetes management. Ann Pharmacother. Mar. 1996;30(3):238-43. [pmid: 8833557].
Jain SK, McVie R, Jaramillo JJ, Palmer M, Smith T, Meachum ZD, et al. The effect of modest vitamin E supplementation on lipid peroxidation products and other cardiovascular risk factors in diabetic patients. Lipids. Mar. 1996;31(Suppl):S87-90. [pmid: 8729100].
Jennings PE, Morgan HC, Barnett AH. Improved diabetes control and knowledge during a diabetes self-help group. Diabetes Educ. Fall. 1987;13(4):390-3. [pmid: 3665724].
Jialal I, Fuller CJ, Huet BA. The effect of alpha-tocopherol supplementation on LDL oxidation. A dose-response study. Arterioscler Thromb Vasc Biol. Feb. 1995;15(2):190-8. [pmid: 7749825].
Jialal I, Grundy SM. Effect of dietary supplementation with alpha-tocopherol on the oxidative modification of low density lipoprotein. J Lipid Res. Jun. 1992;33(6):899-906. [pmid: 1512513].
Jubb RW, Piva S, Beinat L, Dacre J, Gishen P. A one-year, randomised, placebo (saline) controlled clinical trial of 500-730 kDa sodium hyaluronate (Hyalgan) on the radiological change in osteoarthritis of the knee. Int J Clin Pract. Jul-Aug. 2003;57(6):467-74. [pmid: 12918884].
Kagan BL, Sultzer DL, Rosenlicht N, Gerner RH. Oral S-adenosylmethionine in depression: a randomized, double-blind, placebo-controlled trial. Am J Psychiatry. May. 1990;147(5):591-5. [pmid: 2183633].
Kaikkonen J, Nyyssonen K, Tomasi A, Iannone A, Tuomainen TP, Porkkala-Sarataho E, et al. Antioxidative efficacy of parallel and combined supplementation with coenzyme Q10 and d-alpha-tocopherol in mildly hypercholesterolemic subjects: a randomized placebo-controlled clinical study. Free Radic Res. Sep. 2000;33(3):329-40. [pmid: 10993487].
Karhunen L, Franssila-Kallunki A, Rissanen P, Valve R, Kolehmainen M, Rissanen A, et al. Effect of orlistat treatment on body composition and resting energy expenditure during a two-year weight-reduction programme in obese Finns. Int J Obes Relat Metab Disord. Dec. 2000;24(12):1567-72. [pmid: 11126207].
Karlsson J, Sjogren LS, Lohmander LS. Comparison of two hyaluronan drugs and placebo in patients with knee osteoarthritis. A controlled, randomized, double-blind, parallel-design multicentre study. Rheumatology (Oxford). Nov. 2002;41(11):1240-8. [pmid: 12421996].
Kelley D, Bray G, Pi-Sunyer F, Klein S, Hill J, Miles J, et al. Clinical efficacy of orlistat therapy in overweight and obese patientswith insulin-treated type 2 diabetes: a 1-year randomized controlledtrial. Diabetes Care. 2002;25(6):1033-41. [pmid: 12032111].
Keyserling TC, Samuel-Hodge CD, Ammerman AS, Ainsworth BE, Henriquez-Roldan CF, Elasy TA, et al. A randomized trial of an intervention to improve self-care behaviors of African-American women with type 2 diabetes: impact on physical activity. Diabetes Care. Sep. 2002;25(9):1576-83. [pmid: 12196430].
Kibriya MG, Ali L, Banik NG, Khan AK. Home monitoring of blood glucose (HMBG) in Type-2 diabetes mellitus in a developing country. Diabetes Res Clin Pract. Dec. 1999;46(3):253-7. [pmid: 10624792].
Kim HS, Oh JA. Adherence to diabetes control recommendations: impact of nurse telephone calls. J Adv Nurs. Nov. 2003;44(3):256-61. [pmid: 14641395].
Kleefstra N, Houweling ST, Jansman FG, Groenier KH, Gans RO, Meyboom-de Jong B, et al. Chromium treatment has no effect in patients with poorly controlled, insulin-treated type 2 diabetes in an obese Western population: a randomized, double-blind, placebo-controlled trial. Diabetes Care. Mar. 2006;29(3):521-5. [pmid: 16505499].
Krempf M, Louvet JP, Allanic H, Miloradovich T, Joubert JM, Attali JR. Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. May. 2003;27(5):591-7. [pmid: 12704403].
Kwon HS, Cho JH, Kim HS, Song BR, Ko SH, Lee JM, et al. Establishment of blood glucose monitoring system using the internet. Diabetes Care. Feb. 2004;27(2):478-83. [pmid: 14747232].
Lee NA, Reasner CA. Beneficial effect of chromium supplementation on serum triglyceride levels in NIDDM. Diabetes Care. Dec. 1994;17(12):1449-52. [pmid: 7882815].
Leigh-Firbank EC, Minihane AM, Leake DS, Wright JW, Murphy MC, Griffin BA, et al. Eicosapentaenoic acid and docosahexaenoic acid from fish oils: differential associations with lipid responses. Br J Nutr. May. 2002;87(5):435-45. [pmid: 12010583].
Leng GC, Lee AJ, Fowkes FG, Jepson RG, Lowe GD, Skinner ER, et al. Randomized controlled trial of gamma-linolenic acid and eicosapentaenoic acid in peripheral arterial disease. Clin Nutr. Dec. 1998;17(6):265-71. [pmid: 10205349].
Levetan CS, Dawn KR, Robbins DC, Ratner RE. Impact of computer-generated personalized goals on HbA(1c). Diabetes Care. Jan. 2002;25(1):2-8. [pmid: 11772893].
Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. Sep. 2000;248(3):245-54. [pmid: 10971792].
Lohmander LS, Dalen N, Englund G, Hamalainen M, Jensen EM, Karlsson K, et al. Intra-articular hyaluronan injections in the treatment of osteoarthritis of the knee: a randomised, double blind, placebo controlled multicentre trial. Hyaluronan Multicentre Trial Group. Ann Rheum Dis. Jul. 1996;55(7):424-31.
Lucas CP, Boldrin MN, Reaven GM. Effect of orlistat added to diet (30% of calories from fat) on plasma lipids, glucose, and insulin in obese patients with hypercholesterolemia. Am J Cardiol. Apr. 15. 2003;91(8):961-4. [pmid: 12686336].
Lungershausen YK, Abbey M, Nestel PJ, Howe PR. Reduction of blood pressure and plasma triglycerides by omega-3 fatty acids in treated hypertensives. J Hypertens. Sep. 1994;12(9):1041-5. [pmid: 7852747].
Matsuo F, Bergen D, Faught E, Messenheimer JA, Dren AT, Rudd GD, et al. Placebo-controlled study of the efficacy and safety of lamotrigine in patients with partial seizures. U.S. Lamotrigine Protocol 0.5 Clinical Trial Group. Neurology. Nov. 1993;43(11):2284-91. [pmid: 8232944].
McCulloch DK, Mitchell RD, Ambler J, Tattersall RB. Influence of imaginative teaching of diet on compliance and metabolic control in insulin dependent diabetes. Br Med J (Clin Res Ed). Dec. 17. 1983;287(6408):1858-61.
McDougle CJ, Epperson CN, Pelton GH, Wasylink S, Price LH. A double-blind, placebo-controlled study of risperidone addition in serotonin reuptake inhibitor-refractory obsessive-compulsive disorder. Arch Gen Psychiatry. Aug. 2000;57(8):794-801. [pmid: 10920469].
McGavin JK, Mann JI, Skeaff CM, Chisholm A. Comparison of a vitamin E-rich diet and supplemental vitamin E on measures of vitamin E status and lipoprotein profile. Eur J Clin Nutr. Jul. 2001;55(7):555-61. [pmid: 11464229].
Mease PJ, Gladman DD, Keystone EC. Alefacept in combination with methotrexate for the treatment of psoriatic arthritis: results of a randomized, double-blind, placebo-controlled study. Arthritis Rheum. May. 2006;54(5):1638-45. [pmid: 16646026].
Mease PJ, Gladman DD, Ritchlin CT, Ruderman EM, Steinfeld SD, Choy EH, et al. Adalimumab for the treatment of patients with moderately to severely active psoriatic arthritis: results of a double-blind, randomized, placebo-controlled trial. Arthritis Rheum. Oct. 2005;52(10):3279-89. [pmid: 16200601].
Miles JM, Leiter L, Hollander P, Wadden T, Anderson JW, Doyle M, et al. Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. Jul. 2002;25(7):1123-8. [pmid: 12087008].
Mori TA, Vandongen R, Beilin LJ, Burke V, Morris J, Ritchie J. Effects of varying dietary fat, fish, and fish oils on blood lipids in a randomized controlled trial in men at risk of heart disease. Am J Clin Nutr. May. 1994;59(5):1060-8. [pmid: 8172092].
Mottram P, Shige H, Nestel P. Vitamin E improves arterial compliance in middle-aged men and women. Atherosclerosis. Aug. 1999;145(2):399-404. [pmid: 10488969].
Muchmore DB, Springer J, Miller M. Self-monitoring of blood glucose in overweight type 2 diabetic patients. Acta Diabetol. Dec. 1994;31(4):215-9. [pmid: 7888692].
Muscettola G, Galzenati M, Balbi A. SAMe versus placebo: a double blind comparison in major depressive disorders. Adv Biochem Psychopharmacol. 1982;32:151-6. [pmid: 7046362].
Nilsen DW, Albrektsen G, Landmark K, Moen S, Aarsland T, Woie L. Effects of a high-dose concentrate of n-3 fatty acids or corn oil introduced early after an acute myocardial infarction on serum triacylglycerol and HDL cholesterol. Am J Clin Nutr. Jul. 2001;74(1):50-6. [pmid: 11451717].
Osterud B, Elvevoll E, Barstad H, Brox J, Halvorsen H, Lia K, et al. Effect of marine oils supplementation on coagulation and cellular activation in whole blood. Lipids. Dec. 1995;30(12):1111-8. [pmid: 8614301].
Paolisso G, Gambardella A, Giugliano D, Galzerano D, Amato L, Volpe C, et al. Chronic intake of pharmacological doses of vitamin E might be useful in the therapy of elderly patients with coronary heart disease. Am J Clin Nutr. Apr. 1995;61(4):848-52. [pmid: 7702030].
Petrella RJ, DiSilvestro MD, Hildebrand C. Effects of hyaluronate sodium on pain and physical functioning in osteoarthritis of the knee: a randomized, double-blind, placebo-controlled clinical trial. Arch Intern Med. Feb. 11. 2002;162(3):292-8. [pmid: 11822921].
Porkkala-Sarataho EK, Nyyssonen MK, Kaikkonen JE, Poulsen HE, Hayn EM, Salonen RM, et al. A randomized, single-blind, placebo-controlled trial of the effects of 200 mg alpha-tocopherol on the oxidation resistance of atherogenic lipoproteins. Am J Clin Nutr. Nov. 1998;68(5):1034-41. [pmid: 9808219].
Puhl W, Bernau A, Greiling H, Kopcke W, Pforringer W, Steck KJ, et al. Intra-articular sodium hyaluronate in osteoarthritis of the knee: a multicenter, double-blind study. Osteoarthritis Cartilage. Oct. 1993;1(4):233-41. [pmid: 15449510].
Raskind MA, Peskind ER, Wessel T, Yuan W. Galantamine in AD: A 6-month randomized, placebo-controlled trial with a 6-month extension. The Galantamine USA-1 Study Group. Neurology. Jun. 27. 2000;54(12):2261-8. [pmid: 10881250].
Raz I, Soskolne V, Stein P. Influence of small-group education sessions on glucose homeostasis in NIDDM. Diabetes Care. Jan. 1988;11(1):67-71.
Reaven G, Segal K, Hauptman J, Boldrin M, Lucas C. Effect of orlistat-assisted weight loss in decreasing coronary heart disease risk in patients with syndrome X. Am J Cardiol. Apr. 1. 2001;87(7):827-31. [pmid: 11274935].
Ridgeway NA, Harvill DR, Harvill LM, Falin TM, Forester GM, Gose OD. Improved control of type 2 diabetes mellitus: a practical education/behavior modification program in a primary care clinic. South Med J. Jul. 1999;92(7):667-72. [pmid: 10414474].
Rockwood K, Fay S, Song X, MacKnight C, Gorman M. Attainment of treatment goals by people with Alzheimer's disease receiving galantamine: a randomized controlled trial. CMAJ. Apr. 11. 2006;174(8):1099-1105. [pmid: 16554498].
Rockwood K, Mintzer J, Truyen L, Wessel T, Wilkinson D. Effects of a flexible galantamine dose in Alzheimer's disease: a randomised, controlled trial. J Neurol Neurosurg Psychiatry. Nov. 2001;71(5):589-95. [pmid: 11606667].
Rogers SL, Doody RS, Mohs R. Donepezil improves cognition and global function in Alzheimer's disease: a 15-week, double-blind, placebo-controlled study. Donepezil Study Group. Arch Intern Med. 1998;158:1021-31. [pmid: 9588436].
Rogers SL, Farlow MR, Doody RS, Mohs R, Friedhoff LT. A 24-week, double-blind, placebo-controlled trial of donepezil in patients with Alzheimer's disease. Donepezil Study Group. Neurology. Jan. 1998;50(1):136-45. [pmid: 9443470].
Rogers SL, Friedhoff LT. The efficacy and safety of donepezil in patients with Alzheimer's disease: results of a US Multicentre, Randomized, Double-Blind, Placebo-Controlled Trial. The Donepezil Study Group Dementia. Nov-Dec. 1996;7(6):293-303.
Rosler M, Anand R, Cicin-Sain A, Gauthier S, Agid Y, Dal-Bianco P, et al. Efficacy and safety of rivastigmine in patients with Alzheimer's disease: international randomised controlled trial. BMJ. Mar. 6. 1999;318(7184):633-8. [pmid: 10066203].
Rossner S, Sjostrom L, Noack R, Meinders A, Noseda G. Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. Jan. 2000;8(1):49-61. [pmid: 10678259].
Rutten G, van Eijk J, de Nobel E, Beek M, van der Velden H. Feasibility and effects of a diabetes type II protocol with blood glucose self-monitoring in general practice. Fam Pract. Dec. 1990;7(4):273-8. [pmid: 2289639].
Sachdeo RC, Glauser TA, Ritter F, Reife R, Lim P, Pledger G. A double-blind, randomized trial of topiramate in Lennox-Gastaut syndrome. Topiramate YL Study Group. Neurology. Jun. 10. 1999;52(9):1882-7. [pmid: 10371538].
Sachdeo RC, Leroy RF, Krauss GL, Drake ME Jr, Green PM, Leppik IE, et al. Tiagabine therapy for complex partial seizures. A dose-frequency study. The Tiagabine Study Group. Arch Neurol. May. 1997;54(5):595-601. [pmid: 9152116].
Sacks FM, Hebert P, Appel LJ, Borhani NO, Applegate WB, Cohen JD, et al. Short report: the effect of fish oil on blood pressure and high-density lipoprotein-cholesterol levels in phase I of the Trials of Hypertension Prevention. J Hypertens. Feb. 1994;12(2):209-13. [pmid: 8021472].
Sala SF, Miguel RE. Intra-articular hyaluronic acid in the treatment of osteoarthritis of the knee: a short-term study. Eur J Rheumatol Inflamm. 1995;15:33-8.
Salmaggi P, Bressa GM, Nicchia G, Coniglio M, La Greca P, Le Grazie C. Double-blind, placebo-controlled study of S-adenosyl-L-methionine in depressed postmenopausal women. Psychother Psychosom. 1993;59(1):34-40. [pmid: 8441793].
Scale D, Wobig M, Wolpert W. Viscosupplementation of osteoarthritis knees with hylan: a treatment schedule study. Curr Therapeut Res. 1994;55:220-32.
Schmidt D, Jacob R, Loiseau P, Deisenhammer E, Klinger D, Despland A, et al. Zonisamide for add-on treatment of refractory partial epilepsy: a European double-blind trial. Epilepsy Res. May. 1993;15(1):67-73. [pmid: 8325280].
Schwedes U, Siebolds M, Mertes G. Meal-related structured self-monitoring of blood glucose: effect on diabetes control in non-insulin-treated type 2 diabetic patients. Diabetes Care. Nov. 2002;25(11):1928-32. [pmid: 12401734].
Seltzer B, Zolnouni P, Nunez M, Goldman R, Kumar D, Ieni J, et al. Efficacy of donepezil in early-stage Alzheimer disease: a randomized placebo-controlled trial. Arch Neurol. Dec. 2004;61(12):1852-6. [pmid: 15596605].
Shapira NA, Ward HE, Mandoki M, Murphy TK, Yang MC, Blier P, et al. A double-blind, placebo-controlled trial of olanzapine addition in fluoxetine-refractory obsessive-compulsive disorder. Biol Psychiatry. Mar. 1. 2004;55(5):553-5. [pmid: 15023585].
Sharief M, Viteri C, Ben-Menachem E, Weber M, Reife R, Pledger G, et al. Double-blind, placebo-controlled study of topiramate in patients with refractory partial epilepsy. Epilepsy Res. Nov. 1996;25(3):217-24. [pmid: 8956919].
Simmons D, Gamble GD, Foote S, Cole DR, Coster G. The New Zealand Diabetes Passport Study: a randomized controlled trial of the impact of a diabetes passport on risk factors for diabetes-related complications. Diabet Med. Mar. 2004;21(3):214-7. [pmid: 15008829].
Sivenius J, Kalviainen R, Ylinen A, Riekkinen P. Double-blind study of Gabapentin in the treatment of partial seizures. Epilepsia. Jul-Aug. 1991;32(4):539-42. [pmid: 1907907].
Sjostrom L, Rissanen A, Andersen T, Boldrin M, Golay A, Koppeschaar H, et al. Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. Jul. 18. 1998;352(9123):167-72. [pmid: 9683204].
Stampfer MJ, Willett W, Castelli WP, Taylor JO, Fine J, Hennekens CH. Effect of vitamin E on lipids. Am J Clin Pathol. Jun. 1983;79(6):714-6. [pmid: 6342362].
Tamir E, Robinson D, Koren R, Agar G, Halperin N. Intra-articular hyaluronan injections for the treatment of osteoarthritis of the knee: a randomized, double blind, placebo controlled study. Clin Exp Rheumatol. May-Jun. 2001;19(3):265-70. [pmid: 11407078].
Tariot PN, Solomon PR, Morris JC, Kershaw P, Lilienfeld S, Ding C. A 5-month, randomized, placebo-controlled trial of galantamine in AD. The Galantamine USA-10 Study Group. Neurology. Jun. 27. 2000;54(12):2269-76. [pmid: 10881251].
Tassinari CA, Michelucci R, Chauvel P, Chodkiewicz J, Shorvon S, Henriksen O, et al. Double-blind, placebo-controlled trial of topiramate (600 mg daily) for the treatment of refractory partial epilepsy. Epilepsia. Aug. 1996;37(8):763-8. [pmid: 8764816].
Thomas CS, Bottiglieri T, Edeh J, Carney MW, Reynolds EH, Toone BK. The influence of S-adenosylmethionine (SAM) on prolactin in depressed patients. Int Clin Psychopharmacol. Apr. 1987;2(2):97-102. [pmid: 3298421].
Tu KS, McDaniel G, Gay JT. Diabetes self-care knowledge, behaviors, and metabolic control of older adults--the effect of a posteducational follow-up program. Diabetes Educ. Jan-Feb. 1993;19(1):25-30. [pmid: 8458295].
Uthman BM, Rowan AJ, Ahmann PA, Leppik IE, Schachter SC, Sommerville KW, et al. Tiagabine for complex partial seizures: a randomized, add-on, dose-response trial. Arch Neurol. Jan. 1998;55(1):56-62. [pmid: 9443711].
Vanninen E, Uusitupa M, Siitonen O, Laitinen J, Lansimies E. Habitual physical activity, aerobic capacity and metabolic control in patients with newly-diagnosed type 2 (non-insulin-dependent) diabetes mellitus: effect of 1-year diet and exercise intervention. Diabetologia. Apr. 1992;35(4):340-6. [pmid: 1516762].
Vrtovec M, Vrtovec B, Briski A, Kocijancic A, Anderson RA, Radovancevic B. Chromium supplementation shortens QTc interval duration in patients with type 2 diabetes mellitus. Am Heart J. Apr. 2005;149(4):632-6. [pmid: 15990745].
Weinberger M, Kirkman MS, Samsa GP, Shortliffe EA, Landsman PB, Cowper PA, et al. A nurse-coordinated intervention for primary care patients with non-insulin-dependent diabetes mellitus: impact on glycemic control and health-related quality of life. J Gen Intern Med. Feb. 1995;10(2):59-66. [pmid: 7730940].
White N, Carnahan J, Nugent CA, Iwaoka T, Dodson MA. Management of obese patients with diabetes mellitus: comparison of advice education with group management. Diabetes Care. Sep-Oct. 1986;9(5):490-6. [pmid: 3769719].
Wilcock GK, Lilienfeld S, Gaens E. Efficacy and safety of galantamine in patients with mild to moderate Alzheimer's disease: multicentre randomised controlled trial. Galantamine International-1 Study Group. BMJ. Dec. 9. 2000;321(7274):1445-9. [pmid: 11110737].
Wilkinson D, Murray J. Galantamine: a randomized, double-blind, dose comparison in patients with Alzheimer's disease. Int J Geriatr Psychiatry. Sep. 2001;16(9):852-7. [pmid: 11571763].
Willmore LJ, Shu V, Wallin B. Efficacy and safety of add-on divalproex sodium in the treatment of complex partial seizures. The M88-194 Study Group. Neurology. Jan. 1996;46(1):49-53. [pmid: 8559420].
Wing RR, Epstein LH, Nowalk MP, Scott N, Koeske R, Hagg S. Does self-monitoring of blood glucose levels improve dietary compliance for obese patients with type II diabetes?. Am J Med. Nov. 1986;81(5):830-6. [pmid: 3535493].
Wobig M, Dickhut A, Maier R, Vetter G. Viscosupplementation with hylan G-F 20: a 26-week controlled trial of efficacy and safety in the osteoarthritic knee. Clin Ther. May-Jun. 1998;20(3):410-23. [pmid: 9663358].