# References Dataset 1: Back Pain, 216 Trials

Agrifoglio E, Benvenuti M, Gatto P, et al. Aceclofenac: A New NSAID in the Treatment of Acute Lumbago Multicentre Single Blind Study vs. Diclofenac. Acta Therapeutica. 1994;20:33-41.
Alexandre NM, de Moraes MA, Correa Filho HR, et al. Evaluation of a program to reduce back pain in nursing personnel. Rev Saude Publica. 2001;35:356-61. [pmid: 11600924].
Altmaier EM, Lehmann TR, Russell DW, et al. The effectiveness of psychological interventions for the rehabilitation of low back pain: a randomized controlled trial evaluation. Pain. 1992;49:329-35. [pmid: 1408299].
Amlie E, Weber H, Holme I. Treatment of acute low-back pain with piroxicam: results of a double-blind placebo-controlled trial. Spine (Phila Pa 1976). 1987;12:473-6. [pmid: 2957801].
Andersson GB, Lucente T, Davis AM, et al. A comparison of osteopathic spinal manipulation with standard care for patients with low back pain. N Engl J Med. 1999;341:1426-31. [pmid: 10547405].
Aoki T, Kuroki Y, Kageyama T, et al. Multicentre double-blind comparison of piroxicam and indomethacin in the treatment of lumbar diseases. Eur J Rheumatol Inflamm. 1983;6:247-52. [pmid: 6239779].
Arbus L, Fajadet B, Aubert D, et al. Activity of Tetrazepam (Myolastan) in Low Back Pain. A Double-Blind Trial v. Placebo. Clinical Trials Journal. 1990;27:258-67.
Aure OF, Nilsen JH, Vasseljen O. Manual therapy and exercise therapy in patients with chronic low back pain: a randomized, controlled trial with 1-year follow-up. Spine (Phila Pa 1976). 2003;28:525-31. discussion 531–2. [pmid: 12642755].
Babej-Dolle R, Freytag S, Eckmeyer J, et al. Parenteral dipyrone versus diclofenac and placebo in patients with acute lumbago or sciatic pain: randomized observer-blind multicenter study. Int J Clin Pharmacol Ther. 1994;32:204-9. [pmid: 8032581].
Bakshi R, Broll H, Klein G, et al. Treatment of Acute Lumbosacral Back Pain with Diclofenac Resinate. Drug Invest. 1994;8:288-93.
Baratta RR. A double-blind study of cyclobenzaprine and placebo in the treatment of acute musculoskeletal conditions of the low back. Current Therapeutic Research. 1982;32:646-52.
Basler HD, Jakle C, Kroner-Herwig B. Incorporation of cognitive-behavioral treatment into the medical care of chronic low back patients: a controlled randomized study in German pain treatment centers. Patient Educ Couns. 1997;31:113-24. [pmid: 9216352].
Basmajian JV. Acute back pain and spasm. A controlled multicenter trial of combined analgesic and antispasm agents. Spine (Phila Pa 1976). 1989;14:438-9. [pmid: 2524114].
Bendix AF, Bendix T, Lund C, et al. Comparison of three intensive programs for chronic low back pain patients: a prospective, randomized, observer-blinded study with one-year follow-up. Scand J Rehabil Med. 1997;29:81-9. [pmid: 9198257].
Bendix AF, Bendix T, Ostenfeld S, et al. Active treatment programs for patients with chronic low back pain: a prospective, randomized, observer-blinded study. Eur Spine J. 1995;4:148-52. [pmid: 7552649].
Bendix AF, Bendix T, Vaegter K, et al. Multidisciplinary intensive treatment for chronic low back pain: a randomized, prospective study. Cleve Clin J Med. 1996;63:62-9. [pmid: 8590519].
Bendix T, Bendix A, Labriola M, et al. Functional restoration versus outpatient physical training in chronic low back pain: a randomized comparative study. Spine (Phila Pa 1976). 2000;25:2494-2500. [pmid: 11013502].
Bentsen H, Lindgarde F, Manthorpe R. The effect of dynamic strength back exercise and/or a home training program in 57-year-old women with chronic low back pain. Results of a prospective randomized study with a 3-year follow-up period. Spine (Phila Pa 1976). 1997;22:1494-1500. [pmid: 9231969].
Bergquist-Ullman M, Larsson U. Acute low back pain in industry. A controlled prospective study with special reference to therapy and confounding factors. Acta Orthop Scand. 1977:1-117.
Berry H, Hutchinson DR. A multicentre placebo-controlled study in general practice to evaluate the efficacy and safety of tizanidine in acute low-back pain. J Int Med Res. 1988;16:75-82. [pmid: 2967780].
Berry H, Hutchinson DR. Tizanidine and ibuprofen in acute low-back pain: results of a double-blind multicentre study in general practice. J Int Med Res. 1988;16:83-91. [pmid: 2967781].
Berwick DM, Budman S, Feldstein M. No Clinical Effect of Back Schools in an HMO A Randomized Prospective Trial. Spine. 1989;14.
Bianchi M. Evaluation of Cyclobenzaprine for skeletal muscle spasm of local origin, Clinical Evaluation of Flexeril (Cyclobenzaprine HCl/MSD). Minneapolis MN. Postgraduate Medicine Communications. 1978:25-9.
Blazek M, Keszthelyi B, Varhelyi M, et al. Comparative study of Biarison and Voltaren in acute lumbar pain and lumbo-ischialgia. Ther Hung. 1986;34:163-6. [pmid: 2964738].
Blomberg S, Hallin G, Grann K, et al. Manual therapy with steroid injections--a new approach to treatment of low back pain. A controlled multicenter trial with an evaluation by orthopedic surgeons. Spine (Phila Pa 1976). 1994;19:569-77. [pmid: 8184352].
Borenstein DG, Lacks S, Wiesel SW. Cyclobenzaprine and naproxen versus naproxen alone in the treatment of acute low back pain and muscle spasm. Clin Ther. 1990;12:125-31. [pmid: 2141299].
Boyles WF, Glassman JM, Soyka JP. Management of Acute Musculoskeletal Conditions: Thoracolumbar Strain or Sprain: A Double-Blind Evaluation Comparing the Efficacy and Safety of Carisoprodol with Diazepam. Today's Ther Trends. 1983:1-16.
Braun H, Huberty R. Therapy of lumbar sciatica. A comparative clinical study of a corticoid-free monosubstance and a corticoid-containing combination drug. Med Welt. 1982;33:490-1. [pmid: 6211586].
Bronfort G. Chiropractic versus general medical treatment of low back pain: A small scale controlled clinical trial. AJCM. 1989;2:145-50.
Bronfort G, Goldsmith CH, Nelson CF, et al. Trunk exercise combined with spinal manipulative or NSAID therapy for chronic low back pain: a randomized, observer-blinded clinical trial. J Manipulative Physiol Ther. 1996;19:570-82. [pmid: 8976475].
Brown FL Jr, Bodison S, Dixon J, et al. Comparison of diflunisal and acetaminophen with codeine in the treatment of initial or recurrent acute low back strain. Clin Ther. C. 1986;9:52-8. [pmid: 2951012].
Bru E, Mykletun RJ, Svebak S. 1994. Assessment of musculoskeletal and other health complaints in female hospital staff. Appl Ergon. 1994;25:101-5. [pmid: 15676956].
Bruggemann G, Koehler CO, Koch EM. Results of a double-blind study of diclofenac + vitamin B1, B6, B12 versus diclofenac in patients with acute pain of the lumbar vertebrae. A multicenter study. Klin Wochenschr. 1990;68:116-20.
Buswell J. Low Back Pain: a comparison of two treatment programmes. NZ Journal of Physiotherapy. 1982:13-17.
Calmels P, Jacob JF, Fayolle-Minon I, et al. Use of isokinetic techniques vs standard physiotherapy in patients with chronic low back pain. Preliminary results. Ann Readapt Med Phys. 2004;47:20-7. [pmid: 14967569].
Carlsson CP, Sjolund BH. Acupuncture for chronic low back pain: a randomized placebo-controlled study with long-term follow-up. Clin J Pain. 2001;17:296-305. [pmid: 11783809].
Ceccherelli F, Rigoni MT, Gagliardi G, et al. Comparison of superficial and deep acupuncture in the treatment of lumbar myofascial pain: a double-blind randomized controlled study. Clin J Pain. 2002;18:149-53. [pmid: 12048416].
Cherkin DC, Deyo RA, Battie M, et al. A comparison of physical therapy, chiropractic manipulation, and provision of an educational booklet for the treatment of patients with low back pain. N Engl J Med. 1998;339:1021-9. [pmid: 9761803].
Cherkin DC, Eisenberg D, Sherman KJ, et al. Randomized trial comparing traditional Chinese medical acupuncture, therapeutic massage, and self-care education for chronic low back pain. Arch Intern Med. 2001;161:1081-8. [pmid: 11322842].
Chok B, Lee R, Latimer J, et al. Endurance training of the trunk extensor muscles in people with subacute low back pain. Phys Ther. 1999;79:1032-42. [pmid: 10534796].
Coan RM, Wong G, Ku SL, et al. The acupuncture treatment of low back pain: a randomized controlled study. Am J Chin Med. 1980;8:181-9. [pmid: 6446852].
Colberg K, Hettich M, Sigmund R, et al. The efficacy and tolerability of an 8-day administration of intravenous and oral meloxicam: a comparison with intramuscular and oral diclofenac in patients with acute lumbago. German Meloxicam Ampoule Study Group. Curr Med Res Opin. 1996;13:363-77. [pmid: 8862936].
Coomes EN. A comparison between epidural anaesthesia and bed rest in sciatica. Br Med J. 1961;1:20-4. [pmid: 13695285].
Corey DT, Koepfler LE, Etlin D, et al. A limited functional restoration program for injured workers: A randomized trial. Journal of Occupational Rehabilitation. 1996;6:239-49.
Corts Giner JR. Estudio DS 103–282: Relajante Muscular en Lumbalgia Aguda o Lumbago (Estudio Doble Ciego de Tizanidina plus Paracetamol Vs Placebo plus Paracetamol). Rev. Esp. de Cir. Ost. 1989:119-24.
Dalichau S, Scheele K. Effects of elastic lumbar belts on the effect of a muscle training program for patients with chronic back pain. Z Orthop Ihre Grenzgeb. 2000;138:8-16. [pmid: 10730357].
Dalichau S, Scheele K, Perry RM, et al. Ultrasound-aided posture-and motion analysis of the lumbar spine for the evaluation of the efficacy of a back school in the construction industry. Zbl Arbeitsmed. 1999;49:148-56.
Dapas F, Hartman SF, Martinez L, et al. Baclofen for the treatment of acute low-back syndrome. A double-blind comparison with placebo. Spine (Phila Pa 1976). 1985;10:345-9. [pmid: 2931831].
Davies JE, Gibson T, Tester L. The value of exercises in the treatment of low back pain. Rheumatol Rehabil. 1979;18:243-7. [pmid: 160072].
Davoli L, Ciotti G, Biondi M, et al. Piroxicam-Beta-Cyclodextrin in the Treatment of Low-Back-Pain. Current Therapeutic Research. 1989;46:940-7.
Delitto A, Cibulka MT, Erhard RE, et al. Evidence for use of an extension-mobilization category in acute low back syndrome: a prescriptive validation pilot study. Phys Ther. 1993;73:216-22. discussion 223–8. [pmid: 8456141].
Descarreaux M, Normand MC, Laurencelle L, et al. Evaluation of a specific home exercise program for low back pain. J Manipulative Physiol Ther. 2002;25:497-503. [pmid: 12381971].
Dettori JR, Bullock SH, Sutlive TG, et al. The effects of spinal flexion and extension exercises and their associated postures in patients with acute low back pain. Spine (Phila Pa 1976). 1995;20:2303-12. [pmid: 8553118].
Deyo RA, Diehl AK, Rosenthal M. How many days of bed rest for acute low back pain? A randomized clinical trial. N Engl J Med. 1986;315:1064-70. [pmid: 2945109].
Deyo RA, Walsh NE, Martin DC, et al. A controlled trial of transcutaneous electrical nerve stimulation (TENS) and exercise for chronic low back pain. N Engl J Med. 1990;322:1627-34. [pmid: 2140432].
Donaldson S, Romney D, Donaldson M, et al. Randomized study of the application of single motor unit biofeedback training to chronic low pain. Journal of Occupational Rehabilitation. 1994;4:23-37.
Doran DM, Newell DJ. Manipulation in treatment of low back pain: a multicentre study. Br Med J. 1975;2:161-4. [pmid: 123815].
Driessens M, Famaey JP, Orloff S, et al. Efficacy and tolerability of sustained-release ibuprofen in the treatment of patients with chronic back pain. Current Therapeutic Research. 1994;55:1283-92.
Edelist G, Gross AE, Langer F. Treatment of low back pain with acupuncture. Can Anaesth Soc J. 1976;23:303-6. [pmid: 132988].
Elnaggar IM, Nordin M, Sheikhzadeh A, et al. Effects of spinal flexion and extension exercises on low-back pain and spinal mobility in chronic mechanical low-back pain patients. Spine (Phila Pa 1976). 1991;16:967-72. [pmid: 1835157].
Erhard RE, Delitto A, Cibulka MT. Relative effectiveness of an extension program and a combined program of manipulation and flexion and extension exercises in patients with acute low back syndrome. Phys Ther. 1994;74:1093-1100. [pmid: 7991650].
Evans DP, Burke MS, Lloyd KN, et al. Lumbar spinal manipulation on trial. Part I--clinical assessment. Rheumatol Rehabil. 1978;17:46-53. [pmid: 153574].
Farrell JP, Twomey LT. Acute low back pain. Comparison of two conservative treatment approaches. Med J Aust. 1982;1:160-4. [pmid: 6210835].
Franke A, Gebauer S, Franke K, et al. Acupuncture massage vs Swedish massage and individual exercise vs group exercise in low back pain sufferers--a randomized controlled clinical trial in a 2 × 2 factorial design. Forsch Komplementarmed Klass Naturheilkd. 2000;7:286-93. [pmid: 11155022].
Friedrich M, Gittler G, Halberstadt Y, et al. Combined exercise and motivation program: effect on the compliance and level of disability of patients with chronic low back pain: a randomized controlled trial. Arch Phys Med Rehabil. 1998;79:475-87. [pmid: 9596385].
Frost H, Klaber Moffett JA, Moser JS, et al. Randomised controlled trial for evaluation of fitness programme for patients with chronic low back pain. BMJ. 1995;310:151-4. [pmid: 7833752].
Galantino ML, Bzdewka TM, Eissler-Russo JL, et al. The impact of modified Hatha yoga on chronic low back pain: a pilot study. Altern Ther Health Med. 2004;10:56-9.
Garvey TA, Marks MR, Wiesel SW. A prospective, randomized, double-blind evaluation of trigger-point injection therapy for low-back pain. Spine (Phila Pa 1976). 1989;14:962-4. [pmid: 2528826].
Gemignani G, Olivieri I, Ruju G, et al. Transcutaneous electrical nerve stimulation in ankylosing spondylitis: a double-blind study. Arthritis Rheum. 1991;34:788-9. [pmid: 1828944].
Gibson T, Grahame R, Harkness J, et al. Controlled comparison of short-wave diathermy treatment with osteopathic treatment in non-specific low back pain. Lancet. 1985;1:1258-61. [pmid: 2860453].
Gilbert JR, Taylor DW, Hildebrand A, et al. Clinical trial of common treatments for low back pain in family practice. Br Med J (Clin Res Ed). 1985;291:791-4.
Giles LG, Muller R. Chronic spinal pain: a randomized clinical trial comparing medication, acupuncture, and spinal manipulation. Spine (Phila Pa 1976). 2003;28:1490-1502. discussion 1502–3. [pmid: 12865832].
Giles LG, Muller R. Chronic spinal pain syndromes: a clinical pilot trial comparing acupuncture, a nonsteroidal anti-inflammatory drug, and spinal manipulation. J Manipulative Physiol Ther. 1999;22:376-81. [pmid: 10478769].
Glassman J. Management of acute musculoskeletal conditions-thoracolumbar strain or sprain: A double-blind evaluation comparing the efficacy and safety of carisoprodol with cyclobenzaprine hydrochloride. Current Therapeutic Research. 1983;34:917-29.
Godfrey CM, Morgan PP, Schatzker J. A randomized trial of manipulation for low-back pain in a medical setting. Spine (Phila Pa 1976). 1984;9:301-4. [pmid: 6233718].
Gold R. Orphenadrine Citrate: Sedative or Muscle Relaxant. Clinical Therapeutics. 1978;1:451-3.
Goldie I. A clinical trial with indomethacin (indomee(R)) in low back pain and sciatica. Acta Orthop Scand. 1968;39:117-28. [pmid: 4239771].
Grant DJ, Bishop-Miller J, Winchester DM, et al. A randomized comparative trial of acupuncture versus transcutaneous electrical nerve stimulation for chronic back pain in the elderly. Pain. 1999;82:9-13. [pmid: 10422654].
Gunn CC, Milbrandt WE, Little AS, et al. Dry needling of muscle motor points for chronic low-back pain: a randomized clinical trial with long-term follow-up. Spine (Phila Pa 1976). 1980;5:279-91. [pmid: 6446774].
Gur A, Karakoc M, Cevik R, et al. Efficacy of low power laser therapy and exercise on pain and functions in chronic low back pain. Lasers Surg Med. 2003;32:233-8. [pmid: 12605431].
Hadler NM, Curtis P, Gillings DB, et al. A benefit of spinal manipulation as adjunctive therapy for acute low-back pain: a stratified controlled trial. Spine (Phila Pa 1976). 1987;12:702-6. [pmid: 2961085].
Hansen FR, Bendix T, Skov P, et al. Intensive, dynamic back-muscle exercises, conventional physiotherapy, or placebo-control treatment of low-back pain. A randomized, observer-blind trial. Spine (Phila Pa 1976). 1993;18:98-108. [pmid: 8434332].
Harkapaa K, Jarvikoski A, Mellin G, et al. A controlled study on the outcome of inpatient and outpatient treatment of low back pain. Part I. Pain, disability, compliance, and reported treatment benefits three months after treatment. Scand J Rehabil Med. 1989;21:81-9. [pmid: 2526364].
Hemmila HM, Keinanen-Kiukaanniemi SM, Levoska S, et al. Does folk medicine work? A randomized clinical trial on patients with prolonged back pain. Arch Phys Med Rehabil. 1997;78:571-7. [pmid: 9196462].
Hennies OL. A new skeletal muscle relaxant (DS 103-282) compared to diazepam in the treatment of muscle spasm of local origin. J Int Med Res. 1981;9:62-8. [pmid: 6451461].
Hernandez-Reif M, Field T, Krasnegor J, et al. Lower back pain is reduced and range of motion increased after massage therapy. Int J Neurosci. 2001;106:131-45. [pmid: 11264915].
Herzog W, Conway PJ, Willcox BJ. Effects of different treatment modalities on gait symmetry and clinical measures for sacroiliac joint patients. J Manipulative Physiol Ther. 1991;14:104-9. [pmid: 1826920].
Hickey RF. Chronic low back pain: a comparison of diflunisal with paracetamol. N Z Med J. 1982;95:312-4. [pmid: 6212783].
Hides JA, Jull GA, Richardson CA. Long-term effects of specific stabilizing exercises for first-episode low back pain. Spine (Phila Pa 1976). 2001;26:E243-8. [pmid: 11389408].
Hildebrandt VH, Proper KI, van den Berg R, et al. Cesar therapy is temporarily more effective in patients with chronic low back pain than the standard treatment by family practitioner: randomized, controlled and blinded clinical trial with 1 year follow-up. Ned Tijdschr Geneeskd. 2000;144:2258-64. [pmid: 11109471].
Hindle TH 3rd. Comparison of carisoprodol, butabarbital, and placebo in treatment of the low back syndrome. Calif Med. 1972;117:7-11. [pmid: 4262210].
Hingorani K. Diazepam in backache. A double-blind controlled trial. Ann Phys Med. 1966;8:303-6. [pmid: 4224750].
Hingorani K. Orphenadrin-paracetamol in backache-a double-blind controlled trial. Br J Clin Pract. 1971;25:227-31. [pmid: 4253016].
Hingorani K, Biswas AK. Double-blind controlled trial comparing oxyphenbutazone and indomethacin in the treatment of acute low back pain. Br J Clin Pract. 1970;24:120-3. [pmid: 4245599].
Hoehler FK, Tobis JS, Buerger AA. Spinal manipulation for low back pain. JAMA. 1981;245:1835-8. [pmid: 6453240].
Hosie G. The topical NSAID, felbinac, versus oral ibuprofen: a comparison of efficacy in the treatment of acute lower back injury. British Journal of Clinical Research. 1993;4:5-17.
Hsieh CY, Adams AH, Tobis J, et al. Effectiveness of four conservative treatments for subacute low back pain: a randomized clinical trial. Spine (Phila Pa 1976). 2002;27:1142-8. [pmid: 12045509].
Hume Kendall P, Jenkins JM. Exercises for Backache: A Double-Blind Controlled Trial. Physical Medicine Department, Guy's Hospital London. Physiotherapy. 1968;54:154-7.
Hurri H. The Swedish back school in chronic low back pain. Part I. Benefits. Scand J Rehabil Med. 1989;21:33-40. [pmid: 2523558].
Indahl A, Velund L, Reikeraas O. Good prognosis for low back pain when left untampered. A randomized clinical trial. Spine (Phila Pa 1976). 1995;20:473-7. [pmid: 7747232].
Jaffe G. A double-blind, between-patient comparison of alclofenac (‘Prinalgin’) and indomethacin in the treatment of low back pain and sciatica. Curr Med Res Opin. 1974;2:424-9. [pmid: 4281380].
Transcutaneous Electrical Nerve Stimulation (TENS) For Chronic Low Back Pain. Annual meeting of the American Academy of Orthopedic Surgeons. 1997. San Francisco.
Johannsen F, Remvig L, Kryger P, et al. Exercises for chronic low back pain: a clinical trial. J Orthop Sports Phys Ther. 1995;22:52-9. [pmid: 7581431].
Jousset N, Fanello S, Bontoux L, et al. Effects of functional restoration versus 3 hours per week physical therapy: a randomized controlled study. Spine (Phila Pa 1976). 2004;29:487-93. discussion 494. [pmid: 15129059].
Kankaanpaa M, Taimela S, Airaksinen O, et al. The efficacy of active rehabilitation in chronic low back pain. Effect on pain intensity, self-experienced disability, and lumbar fatigability. Spine (Phila Pa 1976). 1999;24:1034-42. [pmid: 10332798].
Keijsers J, Steenbakkers M, Meertens R, et al. The Efficacy of the Back School: A Randomized Trial. Arthritis Care and Research. December. 1990;3(4):204-9.
Keijsers JF, Groenman NH, Gerards FM, et al. A back school in The Netherlands: evaluating the results. Patient Educ Couns. 1989;14:31-44. [pmid: 10313784].
Kellett KM, Kellett DA, Nordholm LA. Effects of an exercise program on sick leave due to back pain. Phys Ther. 1991;71:283-91. discussion 291-3. [pmid: 1826175].
Kerr DP, Walsh DM, Baxter D. Acupuncture in the management of chronic low back pain: a blinded randomized controlled trial. Clin J Pain. 2003;19:364-70. [pmid: 14600536].
Kinalski R, Kuwik W, Pietrzak D. The comparison of the results of manual therapy versus physiotherapy methods used in treatment of patients with low back pain syndromes. J Manual Medicine. 1989;4:44-6.
Kittang G, Melvaer T, Baerheim A. Acupuncture contra antiphlogistics in acute lumbago. Tidsskr Nor Laegeforen. 2001;121:1207-10. [pmid: 11402745].
Klaber Moffett JA, Chase SM, Portek I, et al. A controlled, prospective study to evaluate the effectiveness of a back school in the relief of chronic low back pain. Spine (Phila Pa 1976). 1986;11:120-2. [pmid: 2939571].
Klinger NM, Wilson RR, Kanniainen CM, et al. Intravenous orphenadrine for the treatment of lumbar paravertebral muscle pain. Current Therapeutic Research. 1988;43:247-54.
Koes BW, Bouter LM, van Mameren H, et al. Randomised clinical trial of manipulative therapy and physiotherapy for persistent back and neck complaints: results of one year follow up. BMJ. 1992;304:601-5. [pmid: 1532760].
Kole-Snijders AM, Vlaeyen JW, Goossens ME, et al. Chronic low-back pain: what does cognitive coping skills training add to operant behavioral treatment? Results of a randomized clinical trial. J Consult Clin Psychol. 1999;67:931-44. [pmid: 10596514].
Kovacs FM, Abraira V, Pozo F, et al. Local and remote sustained trigger point therapy for exacerbations of chronic low back pain. A randomized, double-blind, controlled, multicenter trial. Spine (Phila Pa 1976). 1997;22:786-97. [pmid: 9106321].
Kovacs FM, Llobera J, Abraira V, et al. Effectiveness and cost-effectiveness analysis of neuroreflexotherapy for subacute and chronic low back pain in routine general practice: a cluster randomized, controlled trial. Spine (Phila Pa 1976). 2002;27:1149-59. [pmid: 12045510].
Lacey PH, Dodd GD, Shannon DJ. A double blind, placebo controlled study of piroxicam in the management of acute musculoskeletal disorders. Eur J Rheumatol Inflamm. 1984;7:95-104. [pmid: 6443759].
Lankhorst GJ, Van de Stadt RJ, Vogelaar TW, et al. The effect of the Swedish Back School in chronic idiopathic low back pain. A prospective controlled study. Scand J Rehabil Med. 1983;15:141-5. [pmid: 6195731].
Leclaire R, Esdaile JM, Suissa S, et al. Back school in a first episode of compensated acute low back pain: a clinical trial to assess efficacy and prevent relapse. Arch Phys Med Rehabil. 1996;77:673-9. [pmid: 8669994].
Lehmann TR, Russell DW, Spratt KF. The impact of patients with nonorganic physical findings on a controlled trial of transcutaneous electrical nerve stimulation and electroacupuncture. Spine (Phila Pa 1976). 1983;8:625-34. [pmid: 6228019].
Leibing E, Leonhardt U, Koster G, et al. Acupuncture treatment of chronic low-back pain -- a randomized, blinded, placebo-controlled trial with 9-month follow-up. Pain. 2002;96:189-96. [pmid: 11932074].
Lepisto P. A comparative trial of DS 103-282 and placebo in the treatment of acute skeletal spasms due to disorders of the back. Current Therapeutic Research. 1979;26:454-9.
Lidstrom A, Zachrisson M. Physical therapy on low back pain and sciatica. An attempt at evaluation. Scand J Rehabil Med. 1970;2:37-42. [pmid: 4257208].
Lie H, Frey S. Mobilizing or stabilizing exercise in degenerative disk disease in the lumbar region?. Tidsskr Nor Laegeforen. 1999;119:2051-3. [pmid: 10394282].
Lindequist S, Lundberg B, Wikmark R, et al. Information and regime at low back pain. Scand J Rehabil Med. 1984;16:113-6. [pmid: 6238404].
Lindstrom I, Ohlund C, Eek C, et al. The effect of graded activity on patients with subacute low back pain: a randomized prospective clinical study with an operant-conditioning behavioral approach. Phys Ther. 1992;72:279-90. discussion 291-3. [pmid: 1533941].
Linton SJ, Bradley LA, Jensen I, et al. The secondary prevention of low back pain: a controlled study with follow-up. Pain. 1989;36:197-207. [pmid: 2521930].
Listrat V, Dougados M, Chevalier X, et al. Comparison of the analgesic effect of Tenoxicam after oral or intramuscular administration. Drug Invest Suppl. 1990;2:51-2.
Ljunggren AE, Weber H, Kogstad O, et al. Effect of exercise on sick leave due to low back pain. A randomized, comparative, long-term study. Spine (Phila Pa 1976). 1997;22:1610-6. discussion 1617. [pmid: 9253097].
Lonn JH, Glomsrod B, Soukup MG, et al. Active back school: prophylactic management for low back pain. A randomized, controlled, 1-year follow-up study. Spine (Phila Pa 1976). 1999;24:865-71. [pmid: 10327507].
MacDonald RS, Bell CM. An open controlled assessment of osteopathic manipulation in nonspecific low-back pain. Spine (Phila Pa 1976). 1990;15:364-70. [pmid: 2141951].
Malmivaara A, Hakkinen U, Aro T, et al. The treatment of acute low back pain--bed rest, exercises, or ordinary activity?. N Engl J Med. 1995;332:351-5. [pmid: 7823996].
Manniche C, Hesselsoe G, Bentzen L, et al. Clinical trial of intensive muscle training for chronic low back pain. Lancet. 1988;2:1473-6. [pmid: 2904582].
Mannion AF, Muntener M, Taimela S, et al. A randomized clinical trial of three active therapies for chronic low back pain. Spine (Phila Pa 1976). 1999;24:2435-48. [pmid: 10626305].
Marchand S, Charest J, Li J, et al. Is TENS purely a placebo effect? A controlled study on chronic low back pain. Pain. 1993;54:99-106. [pmid: 8378107].
Mathews JA, Mills SB, Jenkins VM, et al. Back pain and sciatica: controlled trials of manipulation, traction, sclerosant and epidural injections. Br J Rheumatol. 1987;26:416-23. [pmid: 2961394].
Matsumo S, Kaneda K, Norhara Y. Clinical evaluation of ketoprofen (Orudis) in lumbago - a double-blind comparison with diclofenac sodium. Br J Clin Pract. 1981;35:266. [pmid: 6459111].
Melzack R, Vetere P, Finch L. Transcutaneous electrical nerve stimulation for low back pain. A comparison of TENS and massage for pain and range of motion. Phys Ther. 1983;63:489-93. [pmid: 6220415].
Mencke VM, Wieden TE, Hoppe M, et al. Acupuncture of shoulder pain and low back pain. Two Prospective double-blind studies. 1988;4:204-215.
Mendelson G, Selwood TS, Kranz H, et al. Acupuncture treatment of chronic back pain. A double-blind placebo-controlled trial. Am J Med. 1983;74:49-55. [pmid: 6217745].
Meng CF, Wang D, Ngeow J, et al. Acupuncture for chronic low back pain in older patients: a randomized, controlled trial. Rheumatology (Oxford). 2003;42:1508-17. [pmid: 12890859].
Milgrom C, Finestone A, Lev B, et al. Overexertional lumbar and thoracic back pain among recruits: a prospective study of risk factors and treatment regimens. J Spinal Disord. 1993;6:187-93. [pmid: 8347966].
Million R, Nilsen KH, Jayson MI, et al. Evaluation of low back pain and assessment of lumbar corsets with and without back supports. Ann Rheum Dis. 1981;40:449-54. [pmid: 6458250].
Moffett JK, Torgerson D, Bell-Syer S, et al. Randomised controlled trial of exercise for low back pain: clinical outcomes, costs, and preferences. BMJ. 1999;319:279-83. [pmid: 10426734].
Moll W. Therapy of acute lumbovertebral syndromes through optimal muscle relaxation using diazepam. Results of a double-blind study on 68 cases. Med Welt. 1973;24:1747-51. [pmid: 4272092].
Molsberger AF, Mau J, Pawelec DB, et al. Does acupuncture improve the orthopedic management of chronic low back pain--a randomized, blinded, controlled trial with 3 months follow up. Pain. 2002;99:579-87. [pmid: 12406534].
Moore SR, Shurman J. Combined neuromuscular electrical stimulation and transcutaneous electrical nerve stimulation for treatment of chronic back pain: a double-blind, repeated measures comparison. Arch Phys Med Rehabil. 1997;78:55-60. [pmid: 9014958].
Moseley L. Combined physiotherapy and education is efficacious for chronic low back pain. Aust J Physiother. 2002;48:297-302. [pmid: 12443524].
Muckle DS. Flurbiprofen for the treatment of soft tissue trauma. Am J Med. 1986;80:76-80.
Newton-John TR, Spence SH, Schotte D. Cognitive-behavioural therapy versus EMG biofeedback in the treatment of chronic low back pain. Behav Res Ther. 1995;33:691-7. [pmid: 7654161].
Nicholas MK, Wilson PH, Goyen J. Comparison of cognitive-behavioral group treatment and an alternative non-psychological treatment for chronic low back pain. Pain. 1992;48:339-47. [pmid: 1534400].
Nicholas MK, Wilson PH, Goyen J. Operant-behavioural and cognitive-behavioural treatment for chronic low back pain. Behav Res Ther. 1991;29:225-38. [pmid: 1831972].
Niemisto L, Lahtinen-Suopanki T, Rissanen P, et al. A randomized trial of combined manipulation, stabilizing exercises, and physician consultation compared to physician consultation alone for chronic low back pain. Spine (Phila Pa 1976). 2003;28:2185-91. [pmid: 14520029].
Nouwen A. EMG biofeedback used to reduce standing levels of paraspinal muscle tension in chronic low back pain. Pain. 1983;17:353-60. [pmid: 6229707].
Ongley MJ, Klein RG, Dorman TA, et al. A new approach to the treatment of chronic low back pain. Lancet. 1987;2:143-6. [pmid: 2439856].
Orava S. Medical treatment of acute low back pain. Diflunisal compared with indomethacin in acute lumbago. Int J Clin Pharmacol Res. 1986;6:45-51. [pmid: 2937744].
Pena M. Etodolac: analgesic effects in musculoskeletal and postoperative pain. Rheumatol Int. 1990;10(Suppl):9-16.
Penttinen J, Nevala-Puranen N, Airaksinen O, et al. Randomized controlled trial of back school with and without peer support. J Occup Rehabil. 2002;12:21-9. [pmid: 11837056].
Petersen T, Kryger P, Ekdahl C, et al. The effect of McKenzie therapy as compared with that of intensive strengthening training for the treatment of patients with subacute or chronic low back pain: A randomized controlled trial. Spine (Phila Pa 1976). 2002;27:1702-9. [pmid: 12195058].
Pipino F, Menarini C, Lombardi G, et al. A direct Myotonolytic (Pridinol Mesilate) for the managemnt of chronic low back pain: A multicentre, comparitive clinical evaluation. European Journal of Clinical Research. 1991;1:55-70.
Pope MH, Phillips RB, Haugh LD, et al. A prospective randomized three-week trial of spinal manipulation, transcutaneous muscle stimulation, massage and corset in the treatment of subacute low back pain. Spine (Phila Pa 1976). 1994;19:2571-7. [pmid: 7855683].
Postacchini F, Facchini M, Palieri P. Efficacy of Various Forms of Conservative Treatment in Low Back Pain: A Comparitive Study. Neuro-Orthopedics. 1988;6:28-35.
Pratzel HG, Alken RG, Ramm S. Efficacy and tolerance of repeated oral doses of tolperisone hydrochloride in the treatment of painful reflex muscle spasm: results of a prospective placebo-controlled double-blind trial. Pain. 1996;67:417-25. [pmid: 8951937].
Preyde M. Effectiveness of massage therapy for subacute low-back pain: a randomized controlled trial. CMAJ. 2000;162:1815-20. [pmid: 10906914].
Rasmussen-Barr E, Nilsson-Wikmar L, Arvidsson I. Stabilizing training compared with manual treatment in sub-acute and chronic low-back pain. Man Ther. 2003;8:233-41. [pmid: 14559046].
Rittweger J, Just K, Kautzsch K, et al. Treatment of chronic lower back pain with lumbar extension and whole-body vibration exercise: a randomized controlled trial. Spine (Phila Pa 1976). 2002;27:1829-34. [pmid: 12221343].
Rose MJ, Reilly JP, Pennie B, et al. Chronic low back pain rehabilitation programs: a study of the optimum duration of treatment and a comparison of group and individual therapy. Spine (Phila Pa 1976). 1997;22:2246-51. discussion 2252–3. [pmid: 9346145].
Salzmann E, Pforringer W, Paal G, et al. Treatment of chronic low-back syndrome with tetrazepam in a placebo controlled double-blind trial. J. Drug Dev. 1992;4:219-28.
Seferlis T, Nemeth G, Carlsson AM, et al. Conservative treatment in patients sick-listed for acute low-back pain: a prospective randomised study with 12 months' follow-up. Eur Spine J. 1998;7:461-70. [pmid: 9883955].
Siegmeth W, Sieberer W. A comparison of the short-term effects of ibuprofen and diclofenac in spondylosis. J Int Med Res. 1978;6:369-74. [pmid: 81154].
Sims-Williams H, Jayson MI, Young SM, et al. Controlled trial of mobilisation and manipulation for low back pain: hospital patients. Br Med J. 1979;2:1318-20. [pmid: 160266].
Soukup MG, Glomsrod B, Lonn JH, et al. The effect of a Mensendieck exercise program as secondary prophylaxis for recurrent low back pain. A randomized, controlled trial with 12-month follow-up. Spine (Phila Pa 1976). 1999;24(15):1585-91. [pmid: 10457579].
Srini NV, Duncan T. Femoral hernia in children. Br J Clin Pract. 1987;41:618. [pmid: 3676073].
Staal JB, Hlobil H, Twisk JW, et al. Graded activity for low back pain in occupational health care: a randomized, controlled trial. Ann Intern Med. 2004;140:77-84. [pmid: 14734329].
Stankovic R, Johnell O. Conservative treatment of acute low-back pain. A prospective randomized trial: McKenzie method of treatment versus patient education in “mini back school”. Spine (Phila Pa 1976). 1990;15:120-3. [pmid: 2139241].
Storheim K, Brox JI, Holm I, et al. Intensive group training versus cognitive intervention in sub-acute low back pain: short-term results of a single-blind randomized controlled trial. J Rehabil Med. 2003;35:132-40. [pmid: 12809196].
Stratz T. Intramuscular etofenamate in the treatment of acute lumbago. Effectiveness and tolerance in comparison with intramuscular diclofenac-Na. Fortschr Med. 1990;108:264-6. [pmid: 2142116].
Stuckey SJ, Jacobs A, Goldfarb J. EMG biofeedback training, relaxation training, and placebo for the relief of chronic back pain. Percept Mot Skills. 1986;63:1023-36. [pmid: 2949196].
Sweetman BJ, Baig A, Parsons DL. Mefenamic acid, chlormezanone-paracetamol, ethoheptazine-aspirin-meprobamate: a comparative study in acute low back pain. Br J Clin Pract. Feb. 1987;41(2):619-24. [pmid: 2960369].
Szpalski M, Hayez JP. How many days of bed rest for acute low back pain? Objective assessment of trunk function. Eur Spine J. 1992;1:29-31. [pmid: 20054944].
Szpalski M, Hayez JP. Objective functional assessment of the efficacy of tenoxicam in the treatment of acute low back pain. A double-blind placebo-controlled study. Br J Rheumatol. 1994;33:74-8. [pmid: 8162464].
Szpalski M, Poty S, Hayez JP, et al. Objective assessment of trunk function in patients with acute low back pain treated with Tenoxicam A prospective controlled study. Neuro-Ortopedics. 1990;10:41-47.
Tervo T, Petaja L, Lepisto P. A controlled clinical trial of a muscle relaxant analgesic combination in the treatment of acute lumbago. Br J Clin Pract. 1976;30:62-4. [pmid: 130920].
Thomas M, Lundberg T. Importance of modes of acupuncture in the treatment of chronic nociceptive low back pain. Acta Anaesthesiol Scand. 1994;38:63-9. [pmid: 8140876].
Timm KE. A randomized-control study of active and passive treatments for chronic low back pain following L5 laminectomy. J Orthop Sports Phys Ther. 1994;20:276-86. [pmid: 7849747].
Torstensen TA, Ljunggren AE, Meen HD, et al. Efficiency and costs of medical exercise therapy, conventional physiotherapy, and self-exercise in patients with chronic low back pain. A pragmatic, randomized, single-blinded, controlled trial with 1-year follow-up. Spine (Phila Pa 1976). 1998;23:2616-24. [pmid: 9854761].
Triano JJ, McGregor M, Hondras MA, et al. Manipulative therapy versus education programs in chronic low back pain. Spine (Phila Pa 1976). 1995;20:948-55. [pmid: 7644961].
Tritilanunt T, Wajanavisit W. The efficacy of an aerobic exercise and health education program for treatment of chronic low back pain. J Med Assoc Thai. 2. 2001;84:S528-33. [pmid: 11853276].
Tsukayama H, Yamashita H, Amagai H, et al. Randomised controlled trial comparing the effectiveness of electroacupuncture and TENS for low back pain: a preliminary study for a pragmatic trial. Acupunct Med. 2002;20:175-80. [pmid: 12512791].
Turner JA. Comparison of group progressive-relaxation training and cognitive-behavioral group therapy for chronic low back pain. J Consult Clin Psychol. 1982;50:757-65. [pmid: 6216275].
Turner JA, Clancy S. Comparison of operant behavioral and cognitive-behavioral group treatment for chronic low back pain. J Consult Clin Psychol. 1988;56:261-6. [pmid: 2967314].
Turner JA, Clancy S, McQuade KJ, et al. Effectiveness of behavioral therapy for chronic low back pain: a component analysis. J Consult Clin Psychol. 1990;58:573-9. [pmid: 2147702].
Turner JA, Jensen MP. Efficacy of cognitive therapy for chronic low back pain. Pain. 1993;52:169-77. [pmid: 8455964].
Underwood MR, Morgan J. The use of a back class teaching extension exercises in the treatment of acute low back pain in primary care. Fam Pract. 1998;15:9-15. [pmid: 9527292].
Valle-Jones JC, Walsh H, O'Hara J, et al. Controlled trial of a back support (‘Lumbotrain’) in patients with non-specific low back pain. Curr Med Res Opin. 1992;12:604-13. [pmid: 1533832].
Van den Hout JH, Vlaeyen JW, Heuts PH, et al. Secondary prevention of work-related disability in nonspecific low back pain: does problem-solving therapy help? A randomized clinical trial. Clin J Pain. 2003;19:87-96. [pmid: 12616178].
Vetter G, Bruggemann G, Lettko M, et al. Shortening diclofenac therapy by B vitamins. Results of a randomized double-blind study, diclofenac 50 mg versus diclofenac 50 mg plus B vitamins, in painful spinal diseases with degenerative changes. Z Rheumatol. 1988;47:351-62. [pmid: 3071032].
Videman T, Heikkila J, Partanen T. Double-blind parallel study of meptazinol versus diflunisal in the treatment of lumbago. Curr Med Res Opin. 1984;9:246-52. [pmid: 6239753].
Videman T, Osterman K. Double-blind parallel study of piroxicam versus indomethacin in the treatment of low back pain. Ann Clin Res. 1984;16:156-60.
Vroomen PC, de Krom MC, Wilmink JT, et al. Lack of effectiveness of bed rest for sciatica. N Engl J Med. 1999;340:418-23. [pmid: 9971865].
Waagen GN, Haldeman S, Cook G, et al. Short term trial of chiropractic adjustments for the relief of chronic low back pain. Manual Medicine. 1986;2:63-7.
Waikakul S, Danputipong P, Soparat K. Topical analgesics, indomethacin plaster and diclofenac emulgel for low back pain: a parallel study. J Med Assoc Thai. 1996;79:486-90. [pmid: 8855630].
Waikakul S, Soparat K. Effectiveness and Safety of Loxoprofen Compared with Naproxen in Nonsurgical Low Back Pain. A Parallel Study. Clin Drug Invest. 1995;10:59-63.
Wang RR, Tronnier V. Effect of acupuncture on pain management in patients before and after lumbar disc protrusion surgery--a randomized control study. Am J Chin Med. 2000;28:25-33. [pmid: 10794114].
Waterworth RF, Hunter IA. An open study of diflunisal, conservative and manipulative therapy in the management of acute mechanical low back pain. N Z Med J. 1985;98:372-5. [pmid: 3157894].
Weber H. Comparison of the effect of diazepam and levomepromazine on pain in patients with acute lumbago-sciatica. J Oslo City Hosp. 1980;30:65-8. [pmid: 6446597].
Weber H, Aasand G. The effect of phenylbutazone on patients with acute lumbago-sciatica. A double blind trial. J Oslo City Hosp. 1980;30:69-72. [pmid: 6446598].
Weber H, Holme I, Amlie E. The natural course of acute sciatica with nerve root symptoms in a double-blind placebo-controlled trial evaluating the effect of piroxicam. Spine (Phila Pa 1976). 1993;18:1433-8. [pmid: 8235813].
Wilkinson MJ. Does 48 hours' bed rest influence the outcome of acute low back pain?. Br J Gen Pract. 1995;45:481-4. [pmid: 7546872].
Worz R, Bolten W, Heller B, et al. Flupirtine in comparison with chlormezanone in chronic musculoskeletal back pain. Results of a multicenter randomized double-blind study. Fortschr Med. 1996;114:500-4. [pmid: 9119352].
Wreje U, Nordgren B, Aberg H. Treatment of pelvic joint dysfunction in primary care--a controlled study. Scand J Prim Health Care. 1992;10:310-5. [pmid: 1480873].
Yamashita H. Are the effects of electro-acupuncture on low back pain equal to those of TENS?. Focus on Alternative and Complementary Therapies. 2001;6:254-5.
Yelland MJ, Glasziou PP, Bogduk N, et al. Prolotherapy injections, saline injections, and exercises for chronic low-back pain: a randomized trial. Spine (Phila Pa 1976). 2004;29:9-16. discussion 16. [pmid: 14699269].
Yeung CK, Leung MC, Chow DH. The use of electro-acupuncture in conjunction with exercise for the treatment of chronic low-back pain. J Altern Complement Med. 2003;9:479-90. [pmid: 14499023].
Yozbatiran N, Yildirim Y, Parlak B. Effects of fitness and aquafitness exercises on physical fitness in patients with chronic low back pain. The Pain Clinic. 2004;16:35-42.